# INTRODUCTION

The 2002 statement of the U.S. Preventive Services Task Force (USPSTF 2002) strongly recommends that clinicians screen men and women 50 years of age or older for colorectal cancer and concludes that there is good evidence that periodic fecal occult blood testing (FOBT) reduces mortality from colorectal cancer. Three randomized controlled trials have demonstrated a 15% to 33% reduction in colorectal cancer mortality with FOBT screening (Mandel 1993; Hardcastle 1996; Kronborg 1996).

Colorectal cancer screening modalities, including guaiac FOBT, are currently covered services under the Medicare program. Medicare allows a payment of $4.50 for the guaiac based fecal occult blood test on an annual basis. The most commonly used guaiac tests under this coverage policy are Hemoccult II and Hemoccult-SENSA. Although the Hemoccult II test was used with rehydration in one of the randomized trials to increase sensitivity (Mandel 1993), this practice is not currently recommended. The practice of rehydration is thought to be associated with an unacceptably high rate of false positive tests, about 9% for rehydrated versus 2% for un-rehydrated FOBT, requiring expensive and invasive diagnostic follow-up. Hemoccult-SENSA has substantially better event test sensitivity than Hemoccult II, but at the cost of a false positive rate which is lower than that for rehydrated Hemoccult although it is higher than that for un-rehydrated Hemoccult II.

Immunochemical fecal occult blood tests (IFOBT) have been developed with the aim of achieving test sensitivity that is equivalent to or better than that of Hemoccult-SENSA while achieving false positive rates lower than SENSA but probably not as low as un-rehydrated FOBT. IFOBT may also be more expensive to produce than the traditional guaiac-based tests. The most recent American Cancer Society recommendations (2003) for colorectal cancer screening, include the statement that immunochemical tests are more patient-friendly, and are likely to be equal or better in sensitivity and specificity than guaiac based tests for the detection of fecal blood (Levin 2003).

A nationally representative survey of primary care physicians conducted in 1999 – 2000 found that Hemoccult-II represented 68% of all FOBT tests that were ordered by physicians, while Hemoccult-SENSA accounted for an additional 13%. The remaining 19% of tests used included some IFOBT tests (Klabunde 2003, Klabunde personal communication). The use of the more sensitive Hemoccult-SENSA or immunochemical tests are expected to increase in the future given the recent recommendations from the American Cancer Society.

The purpose of this report is to compare the guaiac and the immunochemcial fecal occult blood test with respect to the cancers detected, cancer deaths averted, and the costs and cost effectiveness (life years gained and costs) of both types of tests. Further the report is to provide an assessment of the cost-effectiveness of guaiac and immunochemical fecal occult blood tests at the same level of allowed Medicare payment for the test, $4.50, and at higher levels of payment for the IFOBT. Finally under different assumptions about test performance characteristics, we will determine payment levels of IFOBT that result in equivalent cost-effectiveness of IFOBT to guaiac FOBT paid at a level of $4.50. We will refer to this as a threshold payment analysis.

In this report, we will summarize evidence on the test performance characteristics of fecal occult blood tests, in particular measured sensitivity and specificity of the tests for the detection of invasive colorectal cancer and for pre-cancerous lesions. Based on this summary, we will specify the base case test parameter values that represent the best estimate of sensitivity and specificity for each type of test. Because the study designs used to obtain measured values of sensitivity and specificity vary widely and because the degree of available evidence varies across the different types of tests under consideration, we will also specify reasonable upper and lower uncertainty boundaries for the sensitivity and specificity parameter values for each type of test. We will then present a series of simulations that assess the cost-effectiveness of various fecal occult blood tests and produce threshold payment levels for IFOBT in comparison to the most cost effective guaiac FOBT test currently under use (Hemoccult II) and to the guaiac FOBT with the highest sensitivity (Hemoccult SENSA).

We recognize that the results of this analysis, cost-effective ratios and payment thresholds, are only one type of input to the complex decision making process that the Centers for Medicare and Medicaid Services (CMS) must consider in making its coverage policy decisions