# CONCLUSIONS

Because of the high degree of uncertainty about the true test characteristics of the various types of FOBTs, we have conducted a variety of simulations to cover the most plausible combinations of these characteristics for various test combinations, including the most favorable assumptions about the characteristics for IFOBT supported by any evidence.

For each of these assumptions we determined the threshold payment level for IFOBT, the payment level that would result in cost effectiveness equal to that for the comparison base case test with a payment level of $4.50. For less favorable, but plausible, assumptions about the specificity of IFOBT compared to Hemoccult II, the threshold payment is less than $4.50. For more favorable assumptions about the specificity of IFOBT compared to Hemoccult II the threshold payment is in the range of $13 – $14. If the less cost-effective Hemoccult SENSA, rather than Hemoccult II, is considered to be the base case the threshold payment level of IFOBT can be in the range of $17 – $33 depending on whether the lower 95% or the higher 98% specificity value is assumed for IFOBT. Substantially higher threshold payment levels for IFOBT could be obtained if IFOBT test performance characteristics as specified by InSure package insert literature are assumed. However, it is doubtful that these values are truly comparable to the conservative values we have assumed for Hemoccult II and Hemoccult SENSA.