# Technical Addendum

This technical addendum contains intermediate outputs for all the simulations conducted for this report. These extensive spreadsheets are best viewed on a computer screen, but they can also be printed out as explained below.

- There are six work books that contain the follow types of spread-sheets:

Grafiek 1 – A graph showing the life-years gained and cost associated with the various scenarios. These graphs are unlabeled. Corresponding labeled graphs are contained in the main report.

Chart 1 – A graph showing threshold payment levels as a function of assumed sensitivity of the comparison test.

Spread-sheets – A series of spread-sheets. Sheet 1 summarizes, for each scenario, numbers of procedures, changes in colorectal cancer cases, deaths and life-years, total costs, average and incremental cost effectiveness ratios and threshold payment levels. Each additional spreadsheet corresponds to a different assumption about the comparison test. In most cases this is different levels of sensitivity. In the case of compliance comparisons this is different levels of compliance. Each spreadsheet provides all the input assumptions, intermediate output values and final output values that correspond to each of the single points shown on Grafiek 1 and Chart 1. Intermediate output values include numbers and costs of all medical procedures for the non-screening and screening simulation and health states, such as clinical and preclinical occurrences of cancer and adenomas, that occur in the non-screening and screening simulations. For a more detailed list of inputs, intermediate outputs and final outputs see column 1 of the spreadsheets.

When printed out the spreadsheets will require 4 or 6 pages. The first 2 or 3 pages correspond the first column panel and all the rows of the spreadsheet. The second 2 or 3 pages correspond to the second column panel and all the rows of the spreadsheet. The first column panel lists all input assumptions for the simulations and contains all intermediate and final output values for a discount rate of zero percent. The second column panel lists all intermediate and final output values for discount rates of 3% and 5%.

The spreadsheet workbooks are labeled as follows:

Workbook 4010059898s

– For base case, sensitivity is 40% of cancer, 10% for large adenomas, 5% for small adenomas, specificity is 98%. For comparison test, specificity is 98%, sensitivity is varied over a range of up to 100% greater than the base case and according package insert claims for IFOBT. (See Figure 2).

Colonoscopic surveillance for recurrence is performed once every three years following detection of an advanced adenoma, once every five years following the detection of a small adenoma and one every ten years otherwise.

Workbook 4010059895s

– Same as above but for indicated values of sensitivity and specificity.

Workbook 7017099295s

- Same as above but for indicated values of sensitivity and specificity.

Workbook 7017099298s

- Same as above but for indicated values of sensitivity and specificity.

Workbook 4010509898

– Same as above but surveillance is performed once every three years.

Workbook 4010059898opk6090

– Values of sensitivity and specificity for base case as indicated; sensitivity/specificity of comparison test is 70170998. Compliance for base case test is 60% and compliance for comparison test is 90%.

The correspondence between these document files and material in the main text is as follows:

Figures 1,2 and 4 are based on workbook 4010059898s and workbook 4010059895s;

Figure 3 is based on workbook 7017099295s and workbook 7017099298s

Figure 5 is based on workbook 4010509898

Figure 6 is based on workbook 4010059898opk6090