# Graphical representation of threshold analysis values

A graphical solution to the threshold analysis value is presented in Appendix 2.

Figure A1 shows the life years gained (y-axis) relative to the costs of screening (x-axis) for each strategy. Line 1 represents the change in the life years gained relative to the cost of screening annually with a test with 40% sensitivity for colorectal cancer, 20% for large adenomas, and 10% for small adenomas and with specificity of 98% as compared to no screening. Line 2 represents the change in the life years gained relative to the cost of screening with a test with these same test characteristics but compared to a test administered biennially rather than annually. Line 3 compares a test with performance characteristics, which are 75% higher than 40% sensitivity for colorectal cancer as compared to no screening. Line 4 compares a test with 75% higher sensitivity for colorectal cancer as compared to the base case of 40% sensitivity. The inverse of the lines represents the ACER when compared to no screening and the ICER when compared to another screening test. All the points presented represent situations in which the unit cost per FOBT is $4.50. The test with the higher sensitivity has a lower CER (steeper slope) of the line through that point. The question now is how much the unit cost of this test with the 75% higher sensitivity may increase and still result in a CER no greater than the initial CER of the test with the lower sensitivity. The horizontal arrows in Figure A2 show how the cost effectiveness lines change as the unit cost of a screening test is increased. The test cost increase but the life years gained are not affected. Figure A2 also shows the new cost effectiveness line that represents the situation where the unit cost has increased to the point that the CER of the more sensitive test equals the CER of the test with the lower sensitivity at the original, lower, unit cost. This threshold analysis can be applied to CER’s from screening compared to no screening (ACER’s) or to changes in costs and effects from screening compared to alternative screening strategies (ICER’s). Figure A2 also shows a lined that represents the situation in which the unit cost of the more sensitive test has been increased such that the CER is now equal to twice the CER of the less sensitive test at the original cost.

Figure A1 FIGURE NOT AVAILABLE

Figure A2 FIGURE NOT AVAILABLE

Figure A3 adds lines for the ACER and ICER when the new IFOBT has the lower sensitivity value of 95%. In this situation, we draw the horizontal line from the new test to the older test with 98% specificity to illustrate that a decrease in specificity results in a lower cost for the FOBT than for the base of Hemoccult II to achieve comparable cost effectiveness.

Figure A3 FIGURE NOT AVAILABLE