# [MISCAN-COLON model]

This appendix consists of three published papers that describe the MISCAN-COLON model:

Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JDF. The MISCAN-COLON simulation model for the evaluation of colorectal cancer screening. Computers and Biomedical Research. 1999;32:13-33. [pmid: 10066353].
Loeve F, Brown ML, Boer R, van Ballegooijen M, vanOortmarssen GJ, Habbema JDF. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 2000;92:557-563. [pmid: 10749911].
Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JDF. Impact of systematic false-negative test results on the performance of faecal occult blood screening. European Journal of Cancer. 2001;37:912-917. [pmid: 11313180].