# [Submission Memo]

Enclosed please find the final report on the comparison of the cost-effectiveness of several fecal occult blood tests (FOBT) in the context of annual screening in the Medicare population

## INTRODUCTION

This analysis compares the cost-effectiveness of commercially available guaiac-based FOBT (gFOBT) tests with immunochemical FOBT (iFOBT) tests in patients who have never been screened before age 65 and who use FOBT as the only method of screening after age 65. The analysis is based on the MISCAN-COLON computer model. This model was originally developed by researchers at Erasmus University and colleagues under contract to the National Cancer Institute.

## RESULTS OF THE MODEL

- Threshold Payment: One of the results of the model is the threshold payment for iFOBT where the cost-effectiveness of the iFOBT would be equal to the cost-effectiveness of the gFOBT test. The clinical data suggest that iFOBT has a higher sensitivity than the most common gFOBT test, Hemoccult II. Therefore, using these data, the model predicts that iFOBT will prevent more cases of cancer and prevent more deaths due to cancer. However, the model also predicts that under most assumptions, the cost of using the iFOBT test is higher. The model calculates a wide range of price points for the threshold payment. For sensitivity estimates up to 80% and specificity estimate of 95%, the model calculates that the price of iFOBT would have to be less than $0 to have equal cost effectiveness to gFOBT. This is because a high cost is associated with follow up tests for the large number of false positives generated by a lower specificity test. However, at the highest levels of sensitivity, the threshold price of iFOBT is $12. At this sensitivity, the iFOBT test is finding a larger number of additional cancers, improving the cost-effectiveness ratio. The threshold price may be even higher if the specificity is higher than 95%. Overall the model predicted a range of threshold prices of $−4.22 to +$29.02 using sensitivity estimates of 70–87% for cancer and specificity estimates of 95–98%. It is not possible to determine with further precision where the threshold payment would be given the data limitations discussed below.
- Incremental Cost-Effectiveness: Another result of the model is the incremental cost-effectiveness of iFOBT compared to gFOBT. The base case of the model predicts that the incremental cost-effectiveness ratio of iFOBT compared to gFOBT at $28 per test is under $30,000 per life year gained. This result is strongly dependent on the number of cancers avoided that is predicted by the model. The model predicts that under the base case assumptions, approximately 20 cancers and 11 deaths per 1000 patients would be avoided by the use of iFOBT compared to gFOBT over the 30 years of the model. As noted below, the overall number of cancer deaths avoided by gFOBT compared to no screening estimated by the model is high compared to the number measured in a screening trial, although there are many differences between the population studied in the model and in the trial that may explain the higher numbers in the model. Some of the assumptions in the model are not realistic, and may cause the model to overestimate the number of cancer deaths avoided and the incremental cost-effectiveness that would be achieved in a real-world population.
- Sensitivity Analysis: The analysis included several sensitivity analyses. One alternative assumption is more aggressive follow-up to positive FOBT tests (i.e., more frequent colonoscopies). Another alternative assumption is lower compliance levels; in this sensitivity analysis patients would be more compliant with iFOBT than gFOBT because of the relative ease of use of the test. Both of these assumptions lead to a more favorable incremental cost effectiveness of iFOBT compared to gFOBT than the base case assumptions.

## VALIDATION OF MODEL

The model predicts that gFOBT screening would lead to a decrease of 66 cancers per 1000 patients screened over 30 years compared to no screening. There are no data on a population reasonably similar to the Medicare population, as modeled for this analysis, so there is no way to validate whether the model is predicting the correct numbers of cancers. A screening study by Mandel et al.1 found only 39 cancers per 1000 patients over 18 years in a population randomized to usual care. They found a decrease of 7 cancers per 1000 patients screened with gFOBT studied for 18 years compared to no screening. However, there were several differences between this population and the model population, including age range (50 and over), length of follow up (18 years), and that the real-world usual care population may have colonoscopy or other screening in additional to FOBT. Although the authors report that the MISCAN model accurately predicted certain results from Mandel et al. by using parameters similar to the population in the Mandel et al. trial, we do not know how well it models the population of interest to Medicare.

## ASSUMPTIONS IN THE MODEL

The model depends on several input parameters estimated from clinical trial data:

- Sensitivity and specificity of the gFOBT and iFOBT tests: As can be seen from the literature review in Table 1 of the report, there has been substantial variation in the measured sensitivity and specificity in various trials published in the peer-reviewed literature. The sensitivity of the iFOBT test ranges from 70–90% for colon cancer and the specificity is generally estimated at about 95% in the majority of the studies. Published data on iFOBT are based on older tests, some of which are not currently being used. The only data available on the Insure test, which is the newest test under consideration here, are from the package insert and from a presentation at a scientific meeting. These data have not been published in peer review literature, and therefore cannot be fully evaluated for methodological quality and relevance. In addition, because of the limited data available on the Insure test, we do not know the robustness of the estimates of sensitivity and specificity.
- Patient and provider behavior also introduce uncertainty into model results. These assumptions include 100% compliance with the FOBT test and optimal follow-up after a positive test. The model also assumes that patients have never received a screening test before age 65 and use FOBT as the only method of screening. In addition, there is substantial uncertainty around many input parameters to the model, including the underlying incidence of adenomas and other precancerous lesions, and the probability that these lesions will progress to cancer.

## DISCUSSION

The model has simplifying assumptions that we know are not realistic, such as that no one in the population has any screening prior to age 65. These assumptions may lead the model to overestimate the benefit of FOBT screening in a real-world population. It is unknown what effects these assumptions would have on the ability of this model to accurately compare two tests. However, under the broad range of sensitivity analyses performed in the model, the incremental cost effectiveness of iFOBT was still low by most standards (i.e. below $50,000), even at $28 per test. The model predicts a wide range of threshold prices for iFOBT that would make the cost-effectiveness equal to gFOBT; it is not possible to narrow down this range further because of the uncertainty in the available data on the test.

1 Mandel JS, Church TR, Bond JH, Ederer F, Geisser MS, Mongin SJ, Snover DC, Schuman LM. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. Nov. 30. 2000;343(22):1603-1607. [pmid: 11096167].