# References

Ali M, Yaqub M, Haider Z, Anees I, Bhargava S, Gian J. Yield of dual endoscopy for positive fecal occult blood test. American J Gastroenterol. 2003;98:82-85.
Allison JE, Tekawa IS, Ransom LJ, Adrain AL. A comparison of fecal-occult blood tests for colorectal-cancer screening. N Engl J Med. 1996;334:155-159. [pmid: 8531970].
Allison JE, Levin T, Sakoda L, Tucker J, Tekawa I, Pauly MP, et al. The new fecal occult blood tests have poor application sensitivity for significant polyps in average risk subjects. Gastroenterology. 2002:A-592.
Australian Health Technology Advisory Committee. Colorectal cancer screening. 1997. Dec.
Brown ML, Riley GF, Potosky AL, Etzioni RD. Obtaining long-term disease specific costs of care: application to Medicare enrollees diagnosed with colorectal cancer. Medical Care. 1999;37:1249-1259. [pmid: 10599606].
Castiglione G, Zappa M, Grazzini G, Mazzotta A, Biagini M, Salvadori P, Ciatto S. Immunochemical vs guaiac faecal occult blood tests in a population-based screening programme for colorectal cancer. Br J Cancer. 1996;74(1):141-144. [pmid: 8679448].
Chen YD, gladden DR, Kestenbaum DF, Collen MJ. Is there a role for upper gastrointestinal endoscopy in the evaluation of patient with occult blood-positive stool and negative colonoscopy?. Amer J Gastroenterol. 1993;88:2026-2069. [pmid: 8249968].
Church TR, Ederer F, Mandel JS. Fecal occult blood screening in the Minnesota Study: sensitivity of the screening test. J Natl Cancer Inst. 1997;89:1440-1448. [pmid: 9326913].
Cole S, Smith A, Bampton P, Sandford J, Morcom J, Young GP. Screening for colorectal cancer: direct comparison of a brush-sampling fecal immunochemical tests for hemoglobin with Hemoccult SENSA. Gastroenterology. 2003;124:A631. (presented at Digestive Disease Week in Orlando, Florida in May 2003).
Cole SR, Young GP, Esterman A, Cadd B, Morcom J. A randomised trial of the impact of new faecal haemoglobin test technologies on population participation in screening for colorectal cancer. Journal of Medical Screening. 2003;10. (in press).
De Koning HJ, Van Inevedl M, Van Oortamarssen GJ, et al. Breast cancer screening and cost-effectiveness; policy alteernatives, quality of life considerations and the possible impact of uncertain factors. International Journal of Cancer. 1991;49:531-537.
Ee HC, Semmens JB, Hoffman NE. Complete colonoscopy rarely misses cancer. Gastrointestinal Endoscopy. 2002;55(2):167-171. [pmid: 11818917].
Fireman BH, Quesenberry CP, Somkin CP, et al. Cost of care for cancer in a health maintenance organization. Health Care Financing Review. 1997;18:51-76. [pmid: 10175613].
Fleisher M, Scoengold RF. Nichols James H, editor. Point-of-Care Testing: Performance Improvement and Evidence-Based Outcomes. Chapter 12: Occult Blood. NY. Marcel Dekker, Inc. 2003:325-351.
Fleisher M, Winawer SJ, Zauber AG, et al. Accuracy of fecal occult blood test interpretation. Ann Intern Med. 1991;114:875-876. [pmid: 2014949].
Frazier AL, Colditz GA, Fuchs CS, Kuntz KM. Cost-effectiveness of screening for colorectal cancer in the general population. JAMA. 2000;284:1854-1961.
Greegor DH. Diagnosis of large-bowel cancer in the asymptomatic patient. JAMA. 1967;201:943-945. [pmid: 6072632].
Greenberg PD, Bertario L, Gnauck R, Kronborg O, Hardcastle JD, Epstein MS, Sadowski D, Sudduth R, Zuckerman GR, Rockey DC. A prospective multicenter evaluation of new fecal occult blood tests in patients undergoing colonoscopy. Am J Gastroenterol. 2000;95:1331-1338. [pmid: 10811348].
Gyrd-Hansen D, Sogaard J, Kronborg O. Analysis of screening data: colorectal cancer. Int J Epi. 1997;26:1172-1181.
Hardcastle JD, Thomas WM, Chamberlain J, et al. Randomised, controlled trial of faecal occult blood screening for colorectal cancer. Results for first 107,349 subjects. Lancet. 1989;1(8648):1160-1164. [pmid: 2566735].
Hardcastle JD, Bennett DH, Whynes DK. Young GI, Rozen P, Levin B, editors. Mass screening: European/UK perspective. Prevention and early detection of colorectal cancer. London. Saunders. 1996:275-288.
Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomized controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348:1472-1477. [pmid: 8942775].
Hixson LJ, Fennerty M, Sampliner RE, et al. Prospective blinded trial of the colonoscopic miss-rate of large colorectal polyps. Gastrointest Endosc. 1991;37:125-127. [pmid: 2032595].
Hsia PC, Al-Kawas FH. Yield of Upper endoscopy in the evaluation of asymptomatic patients with Hemoccult positive stool after a negative colonoscopy. Amer J Gastroenterol. 1992;87:1571-1574. [pmid: 1442675].
Jorgensen OD, Kronborg O, Fenger C. A randomized study of screening for colorectal cancer using faecal occult blood testing: results after 13 years and seven biennial screening rojunds. Gut. 2002;50:29-32. [pmid: 11772963].
Klabunde CN, Frame P, Jones E, Meadow A, Nadel M, Vernon S. A national survey of primary care physicians' colorectal cancer screening recommendations and practices. Prev Med. 2003;36:352-362. [pmid: 12634026].
Kronborg O, Fenger C, Olsen J, Jorgensen Od, Sondergaard O. Randomized study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348:1467-1471. [pmid: 8942774].
Launoy G, Smith TC, Duffy SW, et al. Colorectal cancer mass-screening: estimation of faecal occult blood test sensitivity, taking into account cancer mean sojourn time. Int J Cancer. 1997;73:220-224. [pmid: 9335446].
Levin B, Brooks D, Smith RA, Stone A. Emerging technologies in screening for colorectal cancer: ct colonography, immunochemical fecal occult blood tests, and stool screening using molecular markers. CA Cancer J Clin. 2003;53:44-55. [pmid: 12568443].
Lieberman DA, Weiss DG. for the VA Cooperative Study Group. One-time screening for colorectal cancer with combined fecal occult-blood testing and examination of the distal colon. New Engl J Med. 2001;345:555-560. [pmid: 11529208].
Loeve F, Boer R, van Ballegooijen M, van Oortmarssen GJ, Habbema JDF. Final Report MISCAN-COLON Microsimulation Model for Colorectal Cancer. 1998. NCI Contract NO1-CN-55186.
Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JDF. The MISCAN-COLON simulation model for the evaluation of colorectal cancer screening. Computers and Biomedical Research. 1999;32:13-33. [pmid: 10066353].
Loeve F, Brown ML, Boer R, van Ballegooijen M, van Oortmarssen GJ, Habbema JDF. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 2000;92:557-563. [pmid: 10749911].
Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JDF. Impact of systematic false-negative test results on the performance of faecal occult blood screening. European Journal of Cancer. 2001;37:912-917. [pmid: 11313180].
Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328:1365-1371. [pmid: 8474513].
Mandel JS, Church TR, Ederer F. Colorectal Cancer Mortality: Effectiveness of Biennial Screening for Fecal Occult Blood. J Natl Cancer Inst. 1999;91:434-437. [pmid: 10070942].
Mysliwiec PA, Brown ML, Klabunde CN, Ransohoff DF. Surveillance colonoscopy for colorectal polyps: recommendations by US gastroenterologists and surgeons. Gastroenterology. 2003;124:A-69. 550.
Nakama H, Kamijo N. Accuracy of immunological fecal occult blood testing for colorectal cancer screening. Prev Med. 1994;23:309-313. [pmid: 8078851].
Nakama H, Yamamoto M, Kamijo N, Li T, Wei N, Fattah AS, Zhang B. Colonoscopic evaluation of immunochemical fecal occult blood test for detection of colorectal neoplasia. Hepato-Gastroenterology. 1999;46(25):228-231. [pmid: 10228797].
National Cancer Institute. Surveillance Research Program, Cancer Statistics Branch; Surveillance, Epidemiology, and End Results (SEER) Program public use CD-ROM (1973–1998), released April 2001, based on August 2000 submission.
Petrelli N, Michalek AM, Freedman A, Baroni M, Mink I, Rodriguez-Bigas M. Immunochemical versus guaiac occult blood stool tests: results of a community-based screening program. Surg Oncol. Feb. 1994;3(1):27-36. [pmid: 8186868].
Pignone M, Campbell MK, Phillips C. Meta-analysis of dietary restriction during fecal occult blood testing. Eff Clin Pract. 2001;4:50-156.
Pignone M, Saha S, Hoerger T, Mandelblatt J. Cost-effectiveness analyses of colorectal cancer screening: a systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2002;137:96-104. [pmid: 12118964].
Prevost TC, Launoy G, Duffy SW, Chen HH. Estimating sensitivity and sojourn time in screening for colorectal cancer: a comparison of statistical approaches. Am J Epidemiol. 1998;148(6):609-619. [pmid: 9753016].
Rasmussen M, Kronborg O. Upper gastrointestinal cancer in a population based screening program with fecal occult blood test for colorectal cancer. Scand J Gastroenterol. 2001;37:95-98. [pmid: 11843044].
Ransohoff DF, Lang CA. Improving the fecal occult blood test. N Engl J Med. 1996;334:189-190. [pmid: 8531978].
Ransohoff DF, Lang CA. Screening for colorectal cancer with the fecal occult blood test: a background paper. Ann Intern Med. 1997;126:811-822. [pmid: 9148658].
Ransohoff DF, Sandler RS. Screening for colorectal cancer. N Engl J Med. 2002;346:40-44. [pmid: 11778002].
Rex DK, Cutler CS, Lemmel GT, Rahmani EY, Clark DW, Helper DJ, Lehman GA, Mark DG. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. 1997;112(1):24-28. [pmid: 8978338].
Rex DK, Rahmani EY, Haseman JH, et al. Relative sensitivity of colonoscopy and barium enema for detection of colorectal cancer in clinical practice [see comments]. Gastroenterology. 1997;112:17-23. [pmid: 8978337].
Robinson MHE, Marks CG, Farrands PA, et al. Population screening for colorectal cancer: comparison between guaiac and immunological faecal occult blood tests. Br J Surg. 1994;81:448-451. [pmid: 8173928].
Rockey DC, Koch J, Cello JP, Sanders LL, McQuaid K. Relative frequency of upper gastrointestinal and colonic lesions in patients with positive fecal occult blood tests. N Engl J Med. 1998;339:153-159. [pmid: 9664091].
Rozen P, Knaani J, Samuel Z. Performance characteristics and comparison of two immunochemical and two guaiac fecal occult blood screening tests for colorectal neoplasia. Digestive Diseases and Sciences. 1007;42:2064-2071. [pmid: 9365136].
Sonnenberg A, Delco F, Inadomi JM. Cost-effectiveness of colonoscopy in screening for colorectal cancer. Annals of Internal Medicine. 2000;133:573-584. [pmid: 11033584].
Thomas WM, Hardcastle JD. Role of upper gastrointestinal investigations in a screening study for colorectal neoplasia. Gut. 1990;31:1294-1297. [pmid: 2253915].
U.S. Preventive Services Task Force. Screening for colorectal cancer: recommendation and rationale. Ann Intern Med. 2002;137:129-131. [pmid: 12118971].
Vijan S, Hwang E, Hofer TP, Hayward RA. Which colon cancer screening test? A comparison of costs, effectiveness and compliance. Am J Med. 2001;111:593-601. [pmid: 11755501].
Wagner JL, Tunis S, Brown M, Ching A, Almeida R. Young GP, Rozen P, Levin B, editors. Cost-effectiveness of colorectal cancer: screening in average risk adults. Prevention and Early Detection of Colorectal Cancer. London. WB Saunders. 1996.
Walter SD, Day NE. Estimation of the duration of a pre-clinical disease state using screening data. Am J Epidemiol. 1983;118:865-886. [pmid: 6650488].
Whynes DK, Walker AR, Hardcastle JD. Cost effective screening strategies for colorectal cancer. J Pub Health Med. 1992;14:43-49. [pmid: 1599742].
Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: Clinical guidelines and rationale. Gastroenterology. 1997;112:594-642. [pmid: 9024315].
Winawer SJ, Fletcher R, Rex D, Bond J, Burt R, Ferrucci J, Ganiats T, Levin T, Woolf S, Johnson D, Kirk L, Litin S. Simang C for the US Multisociety Task Forced on Colorectal Cancer. Colorectal cancer screening and surveillance: Clinical guidelines and rationale. Update based on new evidence. Gastroenterology. 2003;124:544-560. [pmid: 12557158].
Wong WM, Lam SK, Cheung KL, Tong TSM, Rozen P, Young GP, et al. Evaluation of an automated immunochemical fecal occult blood tests for colorectal neoplasia detection in a Chinese population. Cancer. 2003;97:2420-2424. [pmid: 12733140].
Young GP, St. John JB, Winawer SJ, Rozen P. Choice of fecal occult blood tests for colorectal cancer screening: recommendations based on performance characteristics in population studies. Am J Gastroenterology. 2002;97:2499-2507.
Young GP, Macrae FA, ST John DJB. Young GP, Rozen P, Levin B, editors. Clinical methods for early detection: Basis, use and evaluation. Prevention and early detection of colorectal cancer. London. Saunders. 1996:241-270.
Zauber AG, Winawer SJ, Bond JH, Waye JD, Schapiro M, O’Brien MJ, Gottlieb L, Sternberg S. FOBT is of limited value in post-polypectomy colonoscopy surveillance. Gastroenterology. 2002;122:A486.
Zuckerman GR, Prakash C, Askin MP, Lewis BS. AGA technical review on the evaluation and management of occult and obscure gastrointestinal bleeding. Gastroenterology. 2000;118:201-221. [pmid: 10611170].