# Overview

## Objectives

The purpose of this technology assessment is to determine the effectiveness of air-fluidized beds and Group 2 support surfaces as defined by the Centers for Medicare and Medicaid Services (CMS) for the treatment of Stage III or IV pressure ulcers in the home and other settings. Additional goals of this assessment are to determine what constitutes proper wound care while a patient is treated on an air-fluidized bed or a Group 2 support surface. Of particular interest in wound care procedures are what methods of wound debridement and what types of wound dressings are most appropriate for these patients. This assessment will also examine the education, training, and experience requirements needed for nursing or care giving in the home setting when using an air-fluidized bed or a Group 2 support surface.

The Centers for Medicare and Medicaid Services (CMS) have divided support surfaces into three groups. Air-fluidized beds are the only devices included in Group 3. Group 2 support surfaces include powered air flotation beds (low-air-loss therapy), powered pressure-reducing air mattresses (alternating air mattresses), and non-powered advanced pressure reducing mattresses, which can be placed directly over a hospital bed frame (foam, water, and gel mattresses). Group 1 support surfaces are pressure pads, certain mattresses, and overlays for mattresses (foam, water, and gel mattresses).

Current Medicare policy reimburses for home use of air-fluidized beds only when the patient has Stage III or IV pressure ulcers and only after the patient has completed at least a 30 day course of conservative treatment "without progression toward wound healing." Medicare policy states that conservative treatment must include "use of a specialized support surface (Group 2) designed to reduce pressure and shear forces on healing ulcers."

Although support surfaces may prevent development of pressure ulcers in at-risk patients, the present technology assessment considers only the efficacy of support surfaces in the treatment of patients with pressure ulcers. This reflects the interests of CMS, for whom this technology assessment was prepared. Also for this reason, this assessment emphasizes the use of air-fluidized beds in the home setting.

In this latter regard, we examined use of Group 2 and 3 support surfaces in hospitals and nursing facilities for evidence of efficacy that might be transferable to the home setting. However, treatment of pressure ulcers typically involves a variety of procedures all of which are essential to proper healing, but are seldom completely reported in clinical studies of wound healing. Standard care for pressure ulcers usually includes pressure relief and skin protection to prevent progression of the ulcer to advanced stages, debridement of necrotic tissue in Stage III and IV ulcers, wound cleansing, and dressings that promote a moist wound environment. Important wound therapies and care may not be similar or equally available in the hospital or nursing facility and in the home. The lack of reporting of concurrent wound treatment limits the extent to which one can determine whether results obtained in hospitals and nursing facilities can be extended to the home setting.

Pressure ulcers are the result of pressure or shear force on the skin leading to occlusion of capillary blood flow and skin cell death. Capillary occlusion affects primarily areas of the skin that are compressed against the underlying bone when a person sits or lies down. Venous and lymphatic obstruction also occurs, followed by cell death if the pressure is not relieved. Pressure ulcers are characterized by deep tissue necrosis and a loss of volume disproportionately greater than the overlying skin defect. Pressure relieving devices are designed to prevent capillary occlusion by reducing the tissue interface pressure sufficiently enough to prevent capillary closure. These devices may also be designed for heat and moisture control as well as preventing capillary closing.

This assessment addresses six key questions. These are:

- Question 1: Are air-fluidized beds effective in the treatment of Stage III and/or IV pressure ulcers in the home setting? Of particular interest is evidence that the use of air-fluidized beds are superior to the use of Group 2 support surfaces for the healing of Stage III and/or IV pressure ulcers.
- Question 2: Are Group 2 support surfaces effective in the treatment of Stage III and/or IV pressure ulcers in the home setting?
- Question 3: At what stage of ulcer development should air-fluidized beds be used? Of particular interest is whether use of air-fluidized beds prevents transition from Stage III to Stage IV ulcers, and whether a 30-day waiting period (in which a Stage III or IV pressure ulcer has not shown progression toward healing) before switching a patient to an air-fluidized bed is supported by clinical evidence.
- Question 4: What are the requirements (education, training, experience) needed for nursing or care giving in the home setting when using an air-fluidized bed?
- Question 5: What are the requirements (education, training, experience) needed for nursing or care giving in the home setting when using Group 2 support surfaces?
- Question 6: What aspects of wound care constitute proper treatment of patients using air-fluidized beds or Group 2 Support Surfaces? Of particular interest are what types of dressings assist (or hamper) wound healing in patients using air-fluidized beds and what types of debridement assist (or hamper) wound healing in patients using air-fluidized beds?

## Methodology

To identify information for this report, we searched seven electronic databases and identified 421 references on air-fluidized beds and other support surfaces that were relevant to patients with pressure ulcers. We retrieved full articles from this reference list according to specific a priori inclusion criteria that were unique to each of the questions listed above.

To address questions 1 and 2 which consider whether air-fluidized beds and Group 2 support surfaces are effective in the treatment of Stage III and/or Stage IV pressure ulcers, clinical studies had to meet the following inclusion criteria:

1. Clinical studies of air-fluidized beds or Group 2 support surfaces for the treatment of patients with pressure ulcers published after 1985 and have the following characteristics:
  a. A parallel control group (a control group is necessary to determine the effectiveness of the support surfaces compared to conventional treatment)
  b. At least 10 patients in each treatment group.
  c. Performed in the home setting but, if studies in the home setting were not available, clinical studies conducted in other settings were examined.
  d. Patients with Stage III and IV pressure ulcers, or study separately presented the results from such patients (results from studies that combined Stage I and II pressure ulcer data with Stage III and IV pressure ulcer data may not accurately represent the results of patients with more severe pressure ulcer stage that are the focus of this report, therefore, we excluded these studies).
2. One of the following outcome measures must be reported
  a. Number of wounds completely healed during study period
  b. Number of wounds that decreased in size during the study period
  c. Number of wounds that became worse or stayed the same during the study period
  d. Mean time to heal
  e. Time to 50% of wound healed during study period
  f. Mean area of wound reduction
  g. Number of patients needing hospitalization or developing a complication with pressure ulcer care
  h. Length of stay during treatment period
3. Other technology assessments of air-fluidized beds for the treatment of pressure ulcers.
4. English language
5. Published as a full article, not a meeting abstract

To address question 3 which considers at what stage of pressure ulcer development should air-fluidized beds be used, we included studies of wound healing therapies.

1. Clinical studies of air-fluidized beds for the treatment of patients with pressure ulcers published after 1985 and have the following characteristics:
  a. Controlled studies in which some patients received air-fluidized beds upon initial diagnosis and some patients waited 30 days before receiving air-fluidized beds, OR studies that stratified their results according to Stage III and Stage IV pressure ulcers.
  b. At least 10 patients in each treatment group.
  c. Patients with Stage III and IV pressure ulcers, or study separately presented the results from such patients (results from studies that combined Stage I and II pressure ulcer data with Stage III and IV pressure ulcer data may not accurately represent the results of patients with more severe pressure ulcer stage that are the focus of this report, therefore, we excluded these studies).
  d. Report the proportion of Stage III and IV pressure ulcers that did and did not improve during the initial 30 days of treatment (ideally, the proportion of Stage III and IV pressure ulcers to improve while using air-fluidized beds during the initial 30 days should have been reported).
2. Also, studies of treatments for Stage III and IV pressure ulcers, other than support surfaces, that report the proportion of Stage III and IV pressure ulcers that did and did not improve during the first 30 days of treatment from first diagnosis published from 1990 to the present.
3. English language
4. Published as a full article, not a meeting abstract

To address questions 4, 5, and 6 which consider issues of nursing or caregiver training and what aspects of wound care are best for patients using air-fluidized beds or Group 2 support surfaces, the following criteria were used:

1. Clinical studies of air-fluidized beds or Group 2 support surfaces for the treatment of patients with pressure ulcers published after 1985 and have the following:
  - At least 10 patients in each treatment group.
    Information on concurrent wound care is reported.
  a. OR clinical guidelines on the use of air-fluidized beds or Group 2 support surfaces for the treatment of pressure ulcers published from 1985 to the present.
  b. OR manuals for air-fluidized beds or Group 2 support surfaces.
  c. OR review articles offering expert opinion on the use of air-fluidized beds or Group 2 support surfaces for the treatment of pressure ulcers published from 1985 to the present.
2. English language
3. Published as a full article, not a meeting abstract

We then assessed the quality of each study that met the inclusion criteria listed above. We excluded some studies from further consideration because of low quality that had the potential to produce significant bias in the results. Therefore, accurate interpretation and analysis of these results was impossible.

## Findings

### Question 1 Are air-fluidized beds effective in the treatment of Stage III and/or IV pressure ulcers in the home setting? Of particular interest is evidence that the use of air-fluidized beds are superior to the use of Group 2 support surfaces for the healing of Stage III and/or IV pressure ulcers

Only one study, an RCT, met the inclusion criteria for this question. This study compared the efficacy of air-fluidized beds and various conventional therapies in the home environment. However, in this study, the patients on air-fluidized beds received additional wound care therapy and more aggressive nursing care of their wounds. This creates a bias towards additional wound healing in the air-fluidized bed group that renders the results of this study difficult to interpret.

Because clinical studies were not available to draw conclusions about the effectiveness of air-fluidized beds in the home, we relaxed the question-specific inclusion criteria so that studies that evaluated air-fluidized beds in other settings could be assessed. With the new criteria, we identified one additional study. This study, an RCT performed in a hospital setting, found that wound size reduction in larger ulcers was significantly greater in patients on air-fluidized beds than in patients using alternating air mattresses, and that the number of large ulcers improved was also significantly greater in patients on air-fluidized beds than in patients on alternating air mattresses. The precise degree to which these results pertain to patients with Stage III or IV ulcers is not certain, because the authors did not classify ulcers by stage. Thus, the relevance of these results to patients with Stage III and IV ulcers depends on the degree to which ulcer size was related to ulcer stage in these patients. Similarly, the extent to which these results can be carried over to the home setting is not known. Finally, since this study was performed more than 10 years ago, it does not directly address the effectiveness of Group 2 support surfaces as they are now manufactured.

Use of Group 2 and 3 support surfaces in hospitals and nursing facilities were also examined for evidence of efficacy that might be transferable to the home setting. However, treatment of pressure ulcers typically involves a variety of procedures all of which are essential to proper healing, but are seldom completely reported in clinical studies of wound healing. Standard care for pressure ulcers usually includes pressure relief and skin protection to prevent progression of the ulcer to advanced stages, debridement of necrotic tissue in Stage III and IV ulcers, wound cleansing, and dressings that promote a moist wound environment. Important wound therapies and nursing care may have different availabilities in the hospital or nursing facility and in the home. The lack of reporting of concurrent wound treatment limits one's ability to determine the extent of the differences in these availabilities.

### Question 2 Are Group 2 support surfaces effective in the treatment of Stage III and/or IV pressure ulcers in the home setting?

We identified no studies that examined Group 2 support surfaces in the home. Therefore, we relaxed the home setting inclusion criteria so that the effectiveness of Group 2 support surfaces in other settings could be examined. Such studies could offer circumstantial evidence about the effectiveness of these support surfaces in the home setting. Using these relaxed inclusion criteria, three RCTs were found that compared Group 2 support surfaces to Group 1 foam mattresses.

Two of these RCTs, comparing a low-air-loss mattress to a foam overlay found no statistically significant differences between these support surfaces in the promotion of healing in Stage III or IV pressure ulcers. The other RCT, comparing an alternating air mattress to a foam mattress, also found no statistically significant differences in the promotion of healing in Stage III or IV pressure ulcers among these surfaces. One of these studies did find a significantly greater rate of wound size reduction for deep ulcers in patients using low-air-loss mattresses compared to patients using foam mattresses. However, the same study found no statistically significant differences in complete healing of deep ulcers. The other studies also found no difference in the rate of complete healing. These studies may have only had sufficient sample size to detect large differences, but the observed differences in healing and improvement were less than 5%.

These studies indicate that Stage III and IV pressure ulcers progress towards wound healing on these devices, but differences in reporting wound healing outcomes prevents any comparisons across studies that would allow the estimation of the proportion of patients with healing wounds and the proportion of patients with non-healing wounds.

### Question 3 At what stage of ulcer development should air-fluidized beds be used?

There are two aspects to this question. The first is whether use of air-fluidized beds prevents the transition from Stage III to Stage IV pressure ulcers. The second aspect of this question is whether switching patients to air-fluidized beds only if their Stage III or IV pressure ulcers have not shown progression toward healing during a 30-day period of conservative treatment is supported by clinical evidence.

This latter aspect is important because current Medicare policy requires such a waiting period for patients with Stage III or IV pressure ulcers. Although there are no studies of air-fluidized beds that directly addressed this issue, some relevant information can be obtained from studies of other wound care treatments that provide data about wound healing during the first 30 days of treatment. These studies can be assessed for evidence of efficacy. If these studies suggest that other wound care methods do not promote healing in Stage III and IV pressure ulcers, then a 30 day waiting period for the use of an air-fluidized bed may not be justified.

No studies of air-fluidized beds that met our inclusion criteria reported on the effects of these beds on the rate of transition from Stage III to Stage IV ulcers. One study of patients on air-fluidized beds reported that 62% of patients with large ulcers (which are potentially Stage III and IV) experienced an improvement in wound condition and that 38% of patients with these ulcers showed no change or became worse.

Three studies of pressure ulcer therapies other than Group 2 or 3 support surfaces suggest that at least some Stage III and IV pressure ulcers progress towards healing (as indicated by a reduction in wound size or other signs of improvement) during the first 30 days under a variety of treatments. However, these studies also suggest that some patients will not benefit from these treatments, and may even get worse. One study reported that only 4% of patients had deterioration or no improvement using a calcium alginate dressing, and 33% of patients had deterioration or no improvement using dextranomer paste and saline gauze. A second study reported that 37% of ulcers decreased in size and 63% of ulcers increased in size when using a hydrocolloid/alginate dressing. A third study reported that 45% and 48% of pressure ulcers healed in 28 days in patients using foam mattresses and water mattresses, respectively.

The data from these studies are not sufficient to determine the exact proportion of patients who do not improve during the initial 30 days of treatment. Also unknown is the proportion of such patients who might benefit from earlier use of airfluidized beds. When considering the initial treatment for Stage III and IV pressure ulcers, the available clinical evidence is not sufficient to determine which type of patient will benefit from initial conservative treatment alone or which type of patient will benefit when air-fluidized bed therapy is added to the conservative therapy.

### Question 4 What are the requirements (education, training, experience) needed for nursing or care giving in the home setting when using an air-fluidized bed?

No clinical studies were identified that directly addressed this question. Consequently, we sought information from other sources. Two guidelines written by the Office of Heath Technology Assessment (OHTA), and the University Hospital Consortium's Technology Advancement Center, and a user's manual for the Clinitron® Hite-Rite™ air-fluidized therapy contained relevant information. These sources suggest that the following are important considerations for proper patient care while using an air-fluidized bed.

- An initial assessment by a physician to evaluate the patient for home use of an air-fluidized bed
  Supervision of the treatment by an attending physician who examines the patient monthly
  Specially trained nurse consultant to provide training for the patient and caregiver
  Turning schedules to help prevent the complications of immobility and methods for turning patients in these beds
  Patient dehydration
  Patient confusion due to the sensation of floating
  Accumulation of thick pulmonary secretions
  Care of the microsphere beads and clean up of microspheres' leakage to prevent skin irritation of the patient and caregiver
  Knowledge of the control panel for turning on and off the blower that fluidizes the microsphere beads (needed to create a firm support surface for emergency CPR)
  Bed elevation procedures

### Question 5 What are the requirements (education, training, experience) needed for nursing or care giving in the home setting when using Group 2 support surfaces?

No published clinical studies were identified that directly addressed this question. Consequently, we sought information from guidelines and review articles. Information on treatment protocols and patient safety in the use of Group 2 support surfaces were found in two guidelines published by the University Hospital Consortium's Technology Advancement Center and the Support Surface Consensus Panel.

These sources suggest that the following are important considerations for proper patient care while using Group 2 support surfaces.

- Bed movement (alternating air mattresses) can increase agitation and may cause nausea
  Patients can slide and need repositioning
  Turning schedule
  Guidelines for infection control
  Means of rapid deflation for emergency procedures
  Plastic surface may cause increased perspiration
  Need to avoid wrinkled sheets and kinked tubing
  Use of incontinence pads without plastic backs
  Eliminating the use of skin protection devices such as heel and elbow pads
  Absorbent breathable underpads should be used
  Avoid punctures and check inflation levels
  Procedures for cleaning the support surfaces
  Flammability of the device

### Question 6 What aspects of wound care constitute proper treatment of patients using air-fluidized beds or Group 2 Support Surfaces?

No studies were identified that specifically examined wound care procedures, such as method of debridement, types of cleaning solutions, types of dressings, or the use of antibiotics in treating pressure ulcers in patients using air-fluidized beds or Group 2 support surfaces. Consequently, we considered information on concurrent wound care treatments as they appeared in clinical studies. This information may form the basis for designing studies to directly answer this question. In addition, we sought information from clinical guidelines, user manuals, and review articles.

The guidelines published by the US Agency for Healthcare Policy and Research (AHCPR)(now the Agency for Healthcare Research and Quality) in 1994, and the American Medical Directors Association in 1999, provided pressure ulcer treatment recommendations applicable to all patients with pressure ulcers including patients using air-fluidized beds and other support surfaces.

Available wound care guidelines did not specifically indicate which dressings or debridement procedures may work best with patients on air-fluidized beds or Group 2 support surfaces. Published studies of air-fluidized beds and Group 2 support surfaces reported using a variety of debridement, wound cleaning, and dressing methods, but did not report results separately by these procedures. Therefore, conclusions cannot be drawn from these studies about the use and effectiveness of these procedures in patients on air-fluidized beds or Group 2 support surfaces.

The Clinitron® Hite-Rite™ air-fluidized therapy user's manual gives the following recommendations for using wet dressings and soaks.

- Use an IV administration set to slow drip the solution to the area for a wet soak. If a continuous drip is not ordered, it may be necessary to increase the frequency of dressing changes.
  Wrap the area with a plastic wrap, place an impervious dressing on the sheet beneath the site, or use the Hill-Rom
  Impervious Sheet to block the airflow.
  Alternatively, resoak the in-place dressing frequently if asepsis can be maintained.