# Preface

This report is organized into two major sections: 1) Overview containing a short discussion of objectives, methodology, and findings, and 2) Technology Assessment containing background, methodology, results, supplemental analyses, conclusions, tables, and references sections.

In the Overview section, we discuss the scope of the project and the questions to be addressed by this report. Our approach and methods used to address these questions will be outlined and a summary of major findings and conclusions will be presented.

In the Technology Assessment section, the background section provides information related to the particular health condition or illness under evaluation, including details about the epidemiology, diagnosis and treatment of the condition or illness. We provide information about the specific set of procedures analyzed for this report.

The methodology section details the methods we used to evaluate currently available data. We detail the strategies employed for our searches of the literature, which includes an exhaustive list of the electronic databases searched and the protocol for hand-searches of the non-journal literature.

In the results section, the inclusion criteria used to identify and retrieve studies are presented, the quality of the studies is examined, and the key outcome measures are analyzed for each question. Studies with major design flaws that bring into question the validity of the study results are excluded. The results of the analyses are described in the text and presented in evidence tables. Finally, we summarize our conclusions.