# References

1 Nwomeh BC, Yager DR, Cohen IK. Physiology of the chronic wound. Clin Plast Surg. Jul. 1998;25(3):341-356. [pmid: 9696897].
2 Prevention and management of pressure ulcers. Hauppauge (NY). Curative Health Services. 1998:20. (Treatment of chronic wounds; no. 6).
3 Silver FH, Wang MC. A review of the etiology and treatment of skin ulcers with wound dressings: comparison of the effects of occlusive and nonocclusive dressings. J Long Term Eff Med Implants. 1992;2(4):267-288. [pmid: 10148002].
4 Smith DM. Pressure ulcers in the nursing home. Ann Intern Med. Sep. 15. 1995;123(6):433-442. [pmid: 7639444].
5 Szycher M, Lee SJ. Modern wound dressings: a systematic approach to wound healing. J Biomater Appl. Oct. 1992;7(2):142-213. [pmid: 1447701].
6 Young JB, Dobrzanski S. Pressure sores. Epidemiology and current management concepts. Drugs Aging. Jan–Feb. 1992;2(1):42-57. [pmid: 1554973].
7 Brandeis GH, Morris JN, Nash DJ, Lipsitz LA. The epidemiology and natural history of pressure ulcers in elderly nursing home residents. JAMA. Dec. 12. 1990;264(22):2905-2909. [pmid: 2232085].
8 Berlowitz DR, Wilking SV. The short-term outcome of pressure sores. J Am Geriatr Soc. Jul. 1990;38(7):748-752. [pmid: 2370394].
9 Goode PS, Thomas DR. Pressure ulcers. Local wound care. Clin Geriatr Med. Aug. 1997;13(3):543-552. [pmid: 9227943].
10 Wind S, Happ E, Kerstein MD. Pressure ulcers: collaboration in wound care. Is there a reasonable approach. Ostomy Wound Manage. May. 1997;43(4):40-44. 46. 48–50 passim. [pmid: 9205397].
11 Weinstein ML. Update on wound healing: a review of the literature. Mil Med. Sep. 1998;163(9):620-624. [pmid: 9753988].
12 Hanna JR, Giacopelli JA. A review of wound healing and wound dressing products. J Foot Ankle Surg. Jan–Feb. 1997;36(1):2-14. discussion 79. [pmid: 9031020].
13 Falanga V, Eaglstein WH. A therapeutic approach to venous ulcers. J Am Acad Dermatol. May. 1986;14(5 Pt 1):777-784. [pmid: 3519695].
14 Laing P. Diabetic foot ulcers. Am J Surg. Jan. 1994;167(1A):31S-36S. [pmid: 8109682].
15 DMERC supplier manual. Baltimore (MD). Centers for Medicare & Medicaid Services. 1998. Mar. Pressure reducing support surfaces. p. 14.22.1–14.25.1. Also available: http://www.umd.nycpic.com/suppman.html.
16 Remsburg RE, Bennett RG. Pressure-relieving strategies for preventing and treating pressure sores. Clin Geriatr Med. Aug. 1997;13(3):513-541. [pmid: 9227942].
17 CLINITRON RITE-HITE air fluidized therapy unit user manual. Durham (NC). Duke University Medical Center. 1997. Oct. 14. various p. Also available: http://www2.mc.duke.edu/depts/clineng/clinitron.htm.
18 Nimit K. Guidelines for home air-fluidized bed therapy, 1989. Health Technol Assess Rep. 1989;(5):1-11. [pmid: 2627503].
19 Thomas Hess C. Patient support surface selection. Guidelines for choosing pressure reduction devices. Contin Care. Jul–Aug. 1992;11(6):35-37. 50. [pmid: 10148136].
20 Executive Committee Working Group. Recommendations for evaluating effectiveness. [Medicare coverage policy online]. Baltimore (MD). Health Care Financing Administration. Feb. 23. cited 2001 Jul 23. 2001:15. Available: http://www.hcfa.gov/coverage/8b1-I9.htm.
21 Stefanovska A, Vodovnik L, Benko H, Turk R. Treatment of chronic wounds by means of electric and electromagnetic fields. Part 2. Value of FES parameters for pressure sore treatment. Med Biol Eng Comput. May. 1993;31(3):213-220. [pmid: 8412373].
22 Karba R, Vodovnik L, Presern-Strukelj M, Klesnik M. Promoted healing of chronic wounds due to electrical stimulation. Wounds. Jan–Feb. 1991;3(1):16-23.
23 Perdrup A. The healing rate of leg ulcers a clinical and statistical study of 233 patients hospitalized with leg ulcers. Acta Derm Venereol. 1972;52(2):136-140. [pmid: 4126311].
24 Strauss MJ, Gong J, Gary BD, Kalsbeek WD, Spear S. The cost of home air-fluidized therapy for pressure sores. A randomized controlled trial. J Fam Pract. Jul. 1991;33(1):52-59. [pmid: 2056290].
25 Allman RM, Walker JM, Hart MK, Laprade CA, Noel LB, Smith CR. Air-fluidized beds or conventional therapy for pressure sores. A randomized trial. Ann Intern Med. Nov. 1987;107(5):641-648. [pmid: 3310792].
26 Cullum N, Deeks J, Sheldon TA, Song F, Fletcher AW. Beds, mattresses and cushions for pressure sore prevention and treatment. Cochrane Database Syst Rev. 2000;(2):CD001735. [pmid: 10796662].
27 Munro BH, Brown L, Heitman BB. Pressure ulcers: one bed or another?. Geriatr Nurs. Jul–Aug. 1989;10(4):190-192. [pmid: 2777121].
28 Ferrell BA, Osterweil D, Christenson P. A randomized trial of low-air-loss beds for treatment of pressure ulcers [published erratum appears in JAMA 1993 Jun 2;269(21):2739]. JAMA. Jan. 27. 1993;269(4):494-497. [pmid: 8338511].
29 A study of pressure ulcer response to low air loss beds vs. conventional treatment. J Geriatr Dermatol. 1993;2:87.
30 Day A, Leonard F. Seeking quality care for patients with pressure ulcers. Decubitus. Jan. 1993;6(1):32-43. [pmid: 8427642].
31 Devine B. Alternating pressure air mattresses in the management of established pressure sores. J Tissue Viability. 1995;5:94-98.
32 Sayag J, Meaume S, Bohbot S. Healing properties of calcium alginate dressings. J Wound Care. Sep. 1996;5(8):357-362. [pmid: 8954425].
33 Barr JE, Day AL, Weaver VA, Taler GM. Assessing clinical efficacy of a hydrocolloid/alginate dressing on full-thickness pressure ulcers. Ostomy Wound Manage. Apr. 1995;41(3):28-30. 32. 34–6 passim. [pmid: 7546113].
34 Groen HW, Groenier KH, Schuling J. Comparative study of a foam mattress and a water mattress. J Wound Care. Jul. 1999;8(7):333-335. [pmid: 10776222].
35 Gault DZ, editor. Guidelines for the use of pressure relief devices in the treatment and prevention of pressure ulcers. Oak Brook (IL). University Hospital Consortium. 1990. various.
36 Greer DM, Morris J, Walsh NE, Glenn AM, Keppler J. Cost-effectiveness and efficacy of air-fluidized therapy in the treatment of pressure ulcers. J Enterostomal Ther. Nov–Dec. 1988;15(6):247-251. [pmid: 3060503].
37 Bennett RG, Bellantoni MF, Ouslander JG. Air-fluidized bed treatment of nursing home patients with pressure sores. J Am Geriatr Soc. Mar. 1989;37(3):235-242. [pmid: 2918193].
38 Bristow JV, Goldfarb EH, Green M. CLINITRON therapy: is it effective?. Geriatr Nurs. May–Jun. 1987;8(3):120-124. [pmid: 3646981].
39 Krouskop T, van Rijswijk L. Standardizing performance-based criteria for support surfaces. Ostomy Wound Manage. Jan–Feb. 1995;41(1):34-36. 38. 40. 45. [pmid: 7779232].
40 Hasty JH, Krasner D, Kennedy KL. A new tool for evaluating patient support surfaces. Part I: A guideline for making practice decisions. Ostomy Wound Manage. Sep–Oct. 1991;36:51-54. 56. 57. 59. [pmid: 1930586].
41 Land L, Evans D, Geary A, Taylor C. A clinical evaluation of an alternating-pressure mattress replacement system in hospital and residential care settings. J Tissue Viability. Jan. 2000;10(1):6-11. [pmid: 10839090].
42 Warner DJ. A clinical comparison of two pressure-reducing surfaces in the management of pressure ulcers. Decubitus. May. 1992;5(3):52-55. 58. 60. 62. 64. [pmid: 1596352].
43 Scavron C. Clinical investigation to determine an effective protocol for managing pressure on skin and soft tissue. Ostomy Wound Manage. Summer. 1989;23:70-79. [pmid: 2730758].
44 Agency for Health Care Policy and Research (AHCPR). Treatment of pressure ulcers. Clinical practice guideline. Rockville (MD). U.S. Department of Health and Human Services, Public Health Service, AHCPR. Dec. 1994:154. (Clinical practice guideline; no. 15).
45 Gerontological Nursing Interventions Research Center (University of Iowa), Research Development and Dissemination Core. Titler MG, Folkedahl BA, Frantz RA, Goode C. Treatment of pressure ulcers. Iowa City (IA). University of Iowa Gerontological Nursing Interventions Research Center. 1997:22. (Research-based protocol; no. 1997).
46 American Medical Directors Association. Pressure ulcer therapy companion. Columbia (MD). American Medical Directors Association. 1999:35.