# Proceedings Abstract References

Antiniw AS, Lau A, Nelson SJ. ^1^H magnetic resonance spectroscopic imaging as a tool for evaluating patients with recurrent gliomas being considered for treatment with gamma knife radiosurgery. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Ben Sira L, Miller E, Siegal T, Gomori JM. Can proton MR spectroscopy (1H MRS) differentiate between oligodendrogliomas and astrocytomas?. Radiological Society of North America. 2002.
Bizzi A, Danesi U, Broggi G, Pollo B, Castelli G, Savolardo M, et al. H-MR spectroscopic imaging-guided surgery of brain tumors: diagnosis of infiltrative vs circumscribed lesions. Radiological Society of North America. 2001.
Bizzi A, Danesi U, Pollo B, Franzini A, Broggi G, Savolardo M. H-MR spectroscopic imaging-guided surgery of brain tumors and correlation with neuropathology. American Society of Neuroradiology. 2001.
Castillo M, Smith JK, Kwock L. Proton MR spectroscopy of brainstem lesions: preliminary experience. American Society of Neuroradiology. 2001.
Catalaa I, Henry RG, Graves E, Lu Y, Vigneron D, Nelson SJ. Diffusion, perfusion and H1-spectroscopy in patients with newly diagnosed gliomas. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Cha S, Saindane AM, Law M, Knopp EA, Zagzag D. Proton MR spectroscopy of tumefactive demyelinating lesions. American Society of Neuroradiology. 2002.
Cruz LH, Brandao LA, Martins G, Domingues RC, Provenzale JM, Domingues RC. Perfusion MR imaging and proton MR spectroscopy of neoplastic brain tumors. Radiological Society of North America. 2001.
Fan G, Wu Z. Proton MR spectroscopy in the differentiation of high-grade glioma solitary metastases. Radiological Society of North America. 2002.
Fatterpekar G, Delman B, Rosenthal H, Sacher M, Lidov M, Naidich T. Use of diffusion-weighted imaging and MR spectroscopy to distinguish brain abscess from intraparenchymal cystic/nectrotic tumors. American Society of Neuroradiology. 2002.
Fujiwara DT, de Castro CC, Rosemberg S, Rotta MJ, Piva RMV, Crri GG. In patients with brain tumors, can the contralateral brain hemisphere be used as control for single-voxel 1H spectrscopy?. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Gomori JM, Levin N, Rubinstein R, Shoshan Y, Siegal T. Conventional and functional imaging techniques in patients with delayed radiation-induced brain injury (RIBI). Radiological Society of North America. 2001.
Graves EE, Takahashi M, Pirzkall A, Larson D, Verhey LJ, Chang S, et al. Serial ^1^H magnetic resonance spectroscopy imaging of gliomas after fractionated radiation therapy. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Hakyemez B, Parlak M, Tuncel E. Clinical impact of in vivo single-voxel proton MR spectroscopy in neoplastic and nonneoplastic brain disorders. American Society of Neuroradiology. 2001.
Hearshen D, Scarpace L, Patel S, Rock JP, Peck D, Mikkelsen T. Multi-slice proton spectroscopic imaging of delayed radiation necrosis correlated with intraoperative histology. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Herminghaus S, Pilatus U, Lanfermann H, Setzer M, Lang J, Zanella FE. Clinical impact of single voxel in vivo proton MR spectroscopy (1H MRS) in the diagnostic of focal brain lesions – an analysis of 293 cases using cluster and discriminant analysis. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002a;10.
Herminghaus S, Pilatus U, Marquardt G, Möller-Hartmann W, Setzer M, Lanfermann H. Differentiation of low from high grade gliomas: proton MR spectroscopy vs stereotactic biopsy. American Society of Neuroradiology. 2001a.
Herminghaus W, Pilatus U, Matthias S, Lang J, Lanfermann H, Volker S, et al. Pathologic metabolism of neuroepithelial brain tumors: prognostic impact of total choline compounds and lipids as measured with in vivo proton MNR spectroscopy. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001b;9.
Herminghaus W, Pilatus U, Raab P, Lanfermann H, Schlote W, Zanella FE. Impact of in vivo proton MR spectroscopy for the assessment of the proliferative activity in viable and partly necrotic brain tumor tissue. American Society of Neuroradiology. 2001c.
Herminghaus W, Pilatus U, Setzer M, Lang J, Lanfermann H, Schlote W, Zanella FE. Proton MR spectroscopy: a reliable tool for differentiating different oncotypes?. American Society of Neuroradiology. 2002b.
Herminghaus W, Setzer M, Pilatus U, Lang J, Lanfermann H, Zanella FE. Pathologic metabolism of neuroepithelial brain tumors: prognostic impact of total choline compounds and lipids as measured with in vivo proton MNR spectroscopy. American Society of Neuroradiology. 2001d.
Hiltunen Y, Pulkkinen J, Häkkinen AM, Lundbom N, Kauppinen RA. Automatic independent component analysis of^1^H spectroscopic imaging data from human brain tumors. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Hiwatashi A, Moritani T, Kinoshita T, Zhong J, Wang HZ, Shrier DA, et al. Multivoxel MR spectroscopy and echo-planar diffusion-weighted MR imaging in intracranial tumors. American Society of Neuroradiology. 2002.
Howe FA, Murphy M, Wilkins P, Loosemore A, Bell BA, Griffiths JR. Correlation of the^1^H MRS metabolic profile of human brain tumors with patient survival. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Kovanlikaya I, Maya MM, Suri R, Moser FG, Tourje EJ, Pressman BD. Multivoxel MR spectroscopy of glial neoplasms: detection of tumor regrowth after treatment. Radiological Society of North America. 2002.
Law M, Cha S, Knopp EA, Johnson G, Salibi N. Glioma grading with multi-voxel, multi-slice spectroscopy MRI and multi-splice perfusion MRI. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Leeds NE, Jackson E, Kumar A, Singh S, Mahankali S. MR spectroscopy in diagnosis and management of patients with gliomatosis cerebri. American Society of Neuroradiology. 2002.
Lefkowitz D, Read K, Chin LS, Gullapalli RP. Accuracy of 1H MR spectroscopy in the assessment of malignant brain tumors. American Society of Neuroradiology. 2002.
Lefkowitz D, Read K, Chin LS, Gullapalli RP. Treated malignant brain tumor assessment: accuracy of 1H-MR spectroscopy as an independent measure. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;10.
Li X, Lu Y, Nelson SJ. Analysis of spatial extent of the metabolic abnormality for newly diagnosed glioma patients. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Li X, Nelson SJ. Comparison of anatomic and metabolic abnormalities for newly diagnosed glioma patients prior to treatment with fractionated radiation therapy. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Lichy MP, Henze H, Sammet S, Maudsley AA, Bachert P Debus J, et al. Clinical decision making in irradiated gliomas: Value of proton MR spectroscopy compared to FDG-PET and IMT-SPECT. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Lim CCT, Chua VGE, Chai SP, Kong FH. Multi-voxel MR spectroscopy – distinguishing brain tumor from non-tumor. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Lim CCT, Chua VGE, Chai SP, Kong WL, Hui F. Multi-voxel MR spectroscopy: pitfalls and patterns in brain tumor assessment. American Society of Neuroradiology. 2001.
Lin A, Ross B. How accurate is ^1^H MRS in the individual tumor patient?. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Lin A, Shic F, Ross B. Differentiating diffuse brainstem neoplasms using proton magnetic resonance spectrscopy. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Londõno A, Kwock L, Castillo M. Proton MR spectroscopy of meningiomas: alanine is lacking in most. American Society of Neuroradiology. 2002.
Majos C, Alonso J, Arus C, Aguilera C, Serrallonga M, Lopez-Obarrio L, et al. Proton magnetic resonance spectroscopy (1H MRS) of brain tumors at long echo time: assessment of differences between tumor types and their applicability in brain tumor categorization in adults. Radiological Society of North America. 2001.
Majos C, Arus C, Aguilera C, Serrllonga, Aloso J, Gili J. Proton magnetic resonance spectroscopy (1H MRS) of brain meningiomas at long echo time: utility in identification of meningiomas uncertain diagnosis. Radiological Society of North America. 2002.
Mao H, Holder CA, Olson JJ, Brat D, Mukundan S. ^1^H MR spectroscopy imaging directed stereotactic biopsy of previously biopsied suspicious brain lesions with equivocal histologic results. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
McKnight T, Vigneron D, Love T, Lamborn K, Chiu K, Berger M, et al. Comparison of a Cho-NAA index with the MIB-1 proliferative index and cell density of tissue samples from grades II and III glioma. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
McKnight TR, von dem Bussche MH, Vigneron DB, Berger MS, McDermontt MW, Dillon WP, et al. Correlation of 3D MRS imaging tumor index with histology in patients with newly diagnosed gliomas. American Society of Neuroradiology. 2001.
Peck DJ, Hearshen DO, Scarpace LM, Soltanian-Zadeh H, Mikkelsen T. Segmentation of brain tumor boundaries using pattern recognition of magnetic resonance spectroscopy. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Peck DJ, Hearshen DO, Soltanian-Zadeh H, Scarpace LM, Dodge C, Mikkelsen T. Segmentation of brain tumor boundaries using pattern recognition of magnetic resonance spectroscopy. Radiological Society of North America. 2001.
Pilatus U, Reichel P, Herminghaus S, Raab P, Setzer M, Lanfermann H, Zanella FE. 1H MRS of neutral lipids in low and high grade gliomas, recurrent gliomas, metastases, lymphomas, abscesses, and inflammation. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Pilatus U, Reichel P, Raab P, Herminghaus S, Setzer M, Lanfermann H, Zanella FE. MRS detectable lipids signal in low- and high-grade gliomas, recurrent gliomas, metastses, lymphomas, and abscesses. American Society of Neuroradiology. 2001.
Scatliff JH, Kwock L, Varia MA, Walters BB. Brain MR imaging and MR proton spectroscopy in the assessment of cerebral metastases before and after radiosurgery. American Society of Neuroradiology. 2001.
Shah T, Jayasundar R, Singh VP, Sarkar C. Correlation between in vivo and in vitro proton MRS and histology of brain tumors. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Shah T, Jayasundar R, Singh VP, Sarkar C. Grading of gliomas – an in vivo proton MRS study. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Shah T, Jayasundar R, Singh VP, Sarkar C. Proton MRS in the differential diagnosis of intraventricular meningiomas and central neurocytomas. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;10.
Shah T, Jayasundar R, Singh VP, Bal CS, Gaikwad S, Sarkar C. Diagnostic potential of proton MRS in identifying tumor recurrence. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Smith JK, Kwock L, Londono A, Castillo M. Proton MR spectroscopy of brainstem lesions. Radiological Society of North America. 2002.
Szabo De Edelenyi F, Estève F, Grand S, Segebarth C, Rubin C, et al. Classification of brain tumors using 1H MRSI at an echo time of 272 msec in combination with linear discriminant analysis. Strategies to improve the correct classification rate. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Tate AR, Griffiths JR, Howe FA, Pujol J, Arus C. Differentiating types of human brain tumours by MRS. A Comparison of pre-processing methods and echo times. Proceedings of the International Society for Magnetic Resonance in Medicine. 2001;9.
Waldman AD, MacManus DG, Moore EA, Stevens J, Rees JH. Serial short-TE single-voxel MRS in low grade gliomas for early detection of malignant transformation. Proceedings of the International Society for Magnetic Resonance in Medicine. 2002;10.
Yin H, Gao YG, Cai Y, Ma L, Liang Y, Guo XG. Discrimination between brain space occupying lesions by 3D proton MR spectroscopy. Radiological Society of North America. 2002.