# Full Study and In-text References

Adams E. Evaluating diagnostic tests: a guide to the literature. Technology Assessment Program, Management Decision and Research Center, Veterans Administration Health Services Research and Development Service. December. 1997;(4).
Adamson AJ, Rand SD, Prost RW, Kim TA, Schultz C, Haughton VM. Focal brain lesions: effect of single-voxel proton MR spectroscopic findings on treatment decisions. Radiology. 1998;209(1):73-78. [pmid: 9769815].
Alger JR, Frank JA, Bizzi A, Fulham MJ, DeSouza BX, Duhaney MO, et al. Metabolism of human gliomas: assessment with H-1 MR spectroscopy and F-18 fluorodeoxyglucose PET. Radiology. 1990;177(3):633-641. [pmid: 2243962].
Barba I, Moreno A, Martinez-Perez I, Tate AR, Cabanas ME, Baquero M, et al. Magnetic resonance spectroscopy of brain hemangiopericytomas: high myoinositol concentrations and discrimination from meningiomas. Journal of Neurosurgery. 2001;94(1):55-60. [pmid: 11147898].
Barbarella G, Ricci R, Pirini G, Tugnoli V, Tosi MR, Bertoluzza A, et al. In vivo single voxel 1H MRS of glial brain tumors: correlation with tissue histology and in vitro MRS. International Journal of Oncology. 1998;12(2):461-468. [pmid: 9458376].
Bruhn H, Frahm J, Gyngell ML, Merboldt KD, Hanicke W, Sauter R, et al. Noninvasive differentiation of tumors with use of localized H-1 MR spectroscopy in vivo: initial experience in patients with cerebral tumors. Radiology. 1989;172(2):541-548. [pmid: 2748837].
Burtscher IM, Skagerberg G, Geijer B, Englund E, Stahlberg F, Holtas S. Proton MR spectroscopy and preoperative diagnostic accuracy: an evaluation of intracranial mass lesions characterized by stereotactic biopsy findings. AJNR: American Journal of Neuroradiology. 2000;21(1):84-93. [pmid: 10669230].
Butzen J, Prost R, Chetty V, Donahue K, Neppl R, Bowen W, et al. Discrimination between neoplastic and nonneoplastic brain lesions by use of proton MR spectroscopy: the limits of accuracy with a logistic regression model. AJNR: American Journal of Neuroradiology. 2000;21(7):1213-1219. [pmid: 10954271].
Castillo M, Smith JK, Kwock L. Correlation of myo-inositol levels and grading of cerebral astrocytomas. AJNR: American Journal of Neuroradiology. 2000;21(9):1645-1649. [pmid: 11039343].
Chang KH, Song IC, Kim SH, Han MH, Kim HD, Seong SO, et al. In vivo single-voxel proton MR spectroscopy in intracranial cystic masses. AJNR: American Journal of Neuroradiology. 1998;19(3):401-405. [pmid: 9541289].
Chumas P, Condon B, Oluoch-Olunya D, Griffiths S, Hadley D, Teasdale G. Early changes in peritumorous oedema and contralateral white matter after dexamethasone: a study using proton magnetic resonance spectroscopy. Journal of Neurology, Neurosurgery & Psychiatry. 1997;62(6):590-595.
Croteau D, Scarpace L, Hearshen D, Gutierrez J, Fisher JL, Rock JP, et al. Correlation between magnetic resonance spectroscopy imaging and image-guided biopsies: semiquantitative and qualitative histopathological analyses of patients with untreated glioma. Neurosurgery. 2001;49(4):823-829. [pmid: 11564242].
Demaerel P, Johannik K, Van Hecke P, Van Ongeval C, Verellen S, Marchal G, et al. Localized 1H NMR spectroscopy in fifty cases of newly diagnosed intracranial tumors. Journal of Computer Assisted Tomography. 1991;15(1):67-76. [pmid: 1846155].
Domingo Z, Rowe G, Blamire AM, Cadoux-Hudson TA. Role of ischaemia in the genesis of oedema surrounding meningiomas assessed using magnetic resonance imaging and spectroscopy. British Journal of Neurosurgery. 1998;12(5):414-418. [pmid: 10070443].
Dowling C, Bollen AW, Noworolski SM, McDermott MW, Barbaro NM, Day MR, et al. Preoperative proton MR spectroscopic imaging of brain tumors: correlation with histopathologic analysis of resection specimens. AJNR: American Journal of Neuroradiology. 2001;22(4):604-612. [pmid: 11290466].
Esteve F, Rubin C, Grand S, Kolodie H, Le Bas JF. Transient metabolic changes observed with proton MR spectroscopy in normal human brain after radiation therapy. International Journal of Radiation Oncology, Biology, Physics. 1998;40(2):279-286.
Falini A, Calabrese G, Origgi D, Lipari S, Triulzi F, Losa M, et al. Proton magnetic resonance spectroscopy and intracranial tumours: clinical perspectives. Journal of Neurology. 1996;243(10):706-714. [pmid: 8923303].
Fineberg HV, Bauman R, Sosman M. Computerized cranial tomography. Effect on diagnostic and therapeutic plans. JAMA. Jul. 18. 1977;238(3):224-227. [pmid: 406427].
Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr-Jun. 1991;11(2):88-94. [pmid: 1907710].
Fountas KN, Kapsalaki EZ, Gotsis SD, Kapsalakis JZ, Smisson HF III, Johnston KW, et al. In vivo proton magnetic resonance spectroscopy of brain tumors. Stereotactic & Functional Neurosurgery. 2000;74(2):83-94. [pmid: 11251398].
Frahm J, Bruhn H, Hanicke W, Merboldt KD, Mursch K, Markakis E. Localized proton NMR spectroscopy of brain tumors using short-echo time STEAM sequences. Journal of Computer Assisted Tomography. 1991;15(6):915-922. [pmid: 1939768].
Fulham MJ, Bizzi A, Dietz MJ, Shih HH, Raman R, Sobering GS, et al. Mapping of brain tumor metabolites with proton MR spectroscopic imaging: clinical relevance. Radiology. 1992;185(3):675-686. [pmid: 1438744].
Furuya S, Naruse S, Ide M, Morishita H, Kizu O, Ueda S, et al. Evaluation of metabolic heterogeneity in brain tumors using 1H-chemical shift imaging method. NMR in Biomedicine. 1997;10(1):25-30. [pmid: 9251112].
Galanaud D, Chinot O, Nicoli F, Confort-Gouny S, Le Fur Y, Barrie-Attarian M, et al. Use of proton magnetic resonance spectroscopy of the brain to differentiate gliomatosis cerebri from low-grade glioma. Journal of Neurosurgery. 2003;98(2):269-276. [pmid: 12593610].
Go KG, Kamman RL, Mooyaart EL, Heesters MA, Pruim J, Vaalburg W, et al. Localised proton spectroscopy and spectroscopic imaging in cerebral gliomas, with comparison to positron emission tomography. Neuroradiology. 1995;37(3):198-206. [pmid: 7603595].
Go KG, Krikke AP, Kamman RL, Heesters MA. The origin of lactate in peritumoral edema as measured by proton-magnetic resonance spectroscopic imaging. Acta Neurochirurgica - Supplementum. 1997;70:173-175.
Gotsis ED, Fountas K, Kapsalaki E, Toulas P, Peristeris G, Papadakis N. In vivo proton MR spectroscopy: the diagnostic possibilities of lipid resonances in brain tumors. Anticancer Research. 1996;16(3B):1565-1567. [pmid: 8694527].
Graves EE, Nelson SJ, Vigneron DB, Chin C, Verhey L, McDermott M, et al. A preliminary study of the prognostic value of proton magnetic resonance spectroscopic imaging in gamma knife radiosurgery of recurrent malignant gliomas. Neurosurgery. 2000;46(2):319-326. [pmid: 10690720].
Graves EE, Nelson SJ, Vigneron DB, Verhey L, McDermott M, Larson D, et al. Serial proton MR spectroscopic imaging of recurrent malignant gliomas after gamma knife radiosurgery. AJNR: American Journal of Neuroradiology. 2001;22(4):613-624. [pmid: 11290467].
Gupta RK, Cloughesy TF, Sinha U, Garakian J, Lazareff J, Rubino G, et al. Relationships between choline magnetic resonance spectroscopy, apparent diffusion coefficient and quantitative histopathology in human glioma. Journal of Neuro-Oncology. 2000;50(3):215-226. [pmid: 11263501].
Gupta RK, Sinha U, Cloughesy TF, Alger JR. Inverse correlation between choline magnetic resonance spectroscopy signal intensity and the apparent diffusion coefficient in human glioma. Magnetic Resonance in Medicine. 1999;41(1):2-7. [pmid: 10025604].
Hagberg G, Burlina AP, Mader I, Roser W, Radue EW, Seelig J. In vivo proton MR spectroscopy of human gliomas: definition of metabolic coordinates for multi-dimensional classification. Magnetic Resonance in Medicine. 1995;34(2):242-252. [pmid: 7476084].
Hall WA, Liu H, Martin AJ, Truwit CL. Comparison of stereotactic brain biopsy to interventional magnetic-resonance-imaging-guided brain biopsy. Stereotactic & Functional Neurosurgery. 1999;73(1–4):148-153. [pmid: 10853123].
Hall WA, Martin A, Liu H, Truwit CL. Improving diagnostic yield in brain biopsy: coupling spectroscopic targeting with real-time needle placement. Journal of Magnetic Resonance Imaging. 2001;13(1):12-15. [pmid: 11169797].
Harada M, Tanouchi M, Nishitani H, Miyoshi H, Bandou K, Kannuki S. Non-invasive characterization of brain tumor by in-vivo proton magnetic resonance spectroscopy. Japanese Journal of Cancer Research. 1995;86(3):329-332. [pmid: 7744704].
Heesters MA, Go KG, Kamman RL, Mooyaart EL, Meertens H, Paans AM, et al. 11C-tyrosine position emission tomography and 1H magnetic resonance spectroscopy of the response of brain gliomas to radiotherapy. Neuroradiology. 1998;40(2):103-108. [pmid: 9541920].
Heesters MA, Kamman RL, Mooyaart EL, Go KG. Localized proton spectroscopy of inoperable brain gliomas. Response to radiation therapy. Journal of Neuro-Oncology. 1993;17(1):27-35. [pmid: 8120569].
Henriksen O, Wieslander S, Gjerris F, Jensen KM. In vivo 1H-spectroscopy of human intracranial tumors at 1.5 tesla. Preliminary experience at a clinical installation. Acta Radiologica. 1991;32(2):95-99. [pmid: 2031809].
Herminghaus S, Dierks T, Pilatus U, Moller-Hartmann W, Wittsack J, Marquardt G, et al. Determination of histopathological tumor grade in neuroepithelial brain tumors by using spectral pattern analysis of in vivo spectroscopic data. Journal of Neurosurgery. 2003;98(1):74-81. [pmid: 12546355].
Houkin K, Kamada K, Sawamura Y, Iwasaki Y, Abe H, Kashiwaba T. Proton magnetic resonance spectroscopy (1H-MRS) for the evaluation of treatment of brain tumours. Neuroradiology. 1995;37(2):99-103. [pmid: 7761009].
Howe FA, Barton SJ, Cudlip SA, Stubbs M, Saunders DE, Murphy M, et al. Metabolic profiles of human brain tumors using quantitative in vivo 1H magnetic resonance spectroscopy. Magnetic Resonance in Medicine. 2003;49(2):223-232. [pmid: 12541241].
Hubesch B, Marinier DS, Hetherington HP, Twieg DB, Weiner MW. Clinical MRS studies of the brain. Investigative Radiology. 1989;24(12):1039-1042. [pmid: 2558086].
Ikehira H, Miyamoto T, Yasukawa T, Obata T, Katoh H, Koga M, et al. Differences in metabolic and morphological reactions after radiation therapy: proton NMR spectroscopy and imaging of patients with intracranial tumors. Radiation Medicine. 1995;13(5):199-204. [pmid: 8848553].
Ishimaru H, Morikawa M, Iwanaga S, Kaminogo M, Ochi M, Hayashi K. Differentiation between high-grade glioma and metastatic brain tumor using single-voxel proton MR spectroscopy. European Radiology. 2001;11(9):1784-1791. [pmid: 11511902].
Isobe T, Matsumura A, Anno I, Yoshizawa T, Nagatomo Y, Itai Y, et al. Quantification of cerebral metabolites in glioma patients with proton MR spectroscopy using T2 relaxation time correction. Magnetic Resonance Imaging. 2002;20(4):343-349. [pmid: 12165353].
Kadota O, Kohno K, Ohue S, Kumon Y, Sakaki S, Kikuchi K, et al. Discrimination of brain abscess and cystic tumor by in vivo proton magnetic resonance spectroscopy. Neurologia Medico-Chirurgica. 2001;41(3):121-126. [pmid: 11372554].
Kamada K, Houkin K, Abe H, Sawamura Y, Kashiwaba T. Differentiation of cerebral radiation necrosis from tumor recurrence by proton magnetic resonance spectroscopy. Neurologia Medico-Chirurgica. 1997;37(3):250-256. [pmid: 9095625].
Kamada K, Moller M, Saguer M, Ganslandt O, Kaltenhauser M, Kober H, et al. A combined study of tumor-related brain lesions using MEG and proton MR spectroscopic imaging. Journal of the Neurological Sciences. 2001;186(1–2):13-21. [pmid: 11412866].
Kaminogo M, Ishimaru H, Morikawa M, Ochi M, Ushijima R, Tani M, et al. Diagnostic potential of short echo time MR spectroscopy of gliomas with single-voxel and point-resolved spatially localised proton spectroscopy of brain. Neuroradiology. 2001;43(5):353-363. [pmid: 11396738].
Kauppinen RA, Niskanen T, Hakumaki J, Williams SR. Quantitative analysis of ^1^H NMR spectra of human brain. Magnetic Resonance Medicine. 1993;32:140-150.
Kim SH, Chang KH, Song IC, Han MH, Kim HC, Kang HS, et al. Brain abscess and brain tumor: discrimination with in vivo H-1 MR spectroscopy. Radiology. 1997;204(1):239-245. [pmid: 9205254].
Kimura T, Sako K, Gotoh T, Tanaka K, Tanaka T. In vivo single-voxel proton MR spectroscopy in brain lesions with ring-like enhancement. NMR in Biomedicine. 2001;14(6):339-349. [pmid: 11599032].
Kinoshita K, Tada E, Matsumoto K, Asari S, Ohmoto T, Itoh T. Proton MR spectroscopy of delayed cerebral radiation in monkeys and humans after brachytherapy. AJNR: American Journal of Neuroradiology. 1997;18(9):1753-1761. [pmid: 9367328].
Kizu O, Naruse S, Furuya S, Morishita H, Ide M, Maeda T, et al. Application of proton chemical shift imaging in monitoring of gamma knife radiosurgery on brain tumors. Magnetic Resonance Imaging. 1998;16(2):197-204. [pmid: 9508276].
Kugel H, Heindel W, Ernestus RI, Bunke J, du MR, Friedmann G. Human brain tumors: spectral patterns detected with localized H-1 MR spectroscopy. Radiology. 1992;183(3):701-709. [pmid: 1584924].
Langkowski JH, Wieland J, Bomsdorf H, Leibfritz D, Westphal M, Offermann W, et al. Pre-operative localized in vivo proton spectroscopy in cerebral tumors at 4.0 Tesla--first results. Magnetic Resonance Imaging. 1989;7(5):547-555. [pmid: 2607903].
Law M, Cha S, Knopp EA, Johnson G, Arnett J, Litt AW. High-grade gliomas and solitary metastases: differentiation by using perfusion and proton spectroscopic MR imaging. Radiology. 2002;222(3):715-721. [pmid: 11867790].
Lin A, Bluml S, Mamelak AN. Efficacy of proton magnetic resonance spectroscopy in clinical decision making for patients with suspected malignant brain tumors. Journal of Neuro-Oncology. 1999;45(1):69-81. [pmid: 10728912].
Lin AP, Ross BD. Short-echo time proton MR spectroscopy in the presence of gadolinium. Journal of Computer Assisted Tomography. 2001;25(5):705-712. [pmid: 11584229].
Luan W, Zhang J. In vivo hydrogen-1 magnetic resonance spectroscopy study of human intracranial tumors. Chinese Medical Journal. 1998;111(1):56-58. [pmid: 10322655].
Mader I, Roser W, Hagberg G, Schneider M, Sauter R, Seelig J, et al. Proton chemical shift imaging, metabolic maps, and single voxel spectroscopy of glial brain tumors. Magma. 1996;4(2):139-150. [pmid: 8875400].
Majos C, Alonso J, Aguilera C, Serrallonga M, Perez-Martin J, Acebes JJ, et al. Proton magnetic resonance spectroscopy ((1)H MRS) of human brain tumours: assessment of differences between tumour types and its applicability in brain tumour categorization. European Radiology. 2003;13(3):582-591. [pmid: 12594562].
Manton DJ, Lowry M, Rowland-Hill C, Crooks D, Mathew B, Turnbull LW. Combined proton MR spectroscopy and dynamic contrast enhanced MR imaging of human intracranial tumours in vivo. NMR in Biomedicine. 2000;13(8):449-459. [pmid: 11252030].
Maris JM, Evans AE, McLaughlin AC, D'Angio GJ, Bolinger L, Manos H, Chance B. 31P nuclear magnetic resonance spectroscopic investigation of human neuroblastoma in situ. N Engl J Med. Jun. 6. 1985;312(23):1500-1505. [pmid: 3990750].
McBride DQ, Miller BL, Nikas DL, Buchthal S, Chang L, Chiang F, et al. Analysis of brain tumors using 1H magnetic resonance spectroscopy. Surgical Neurology. 1995;44(2):137-144. [pmid: 7502203].
McKnight TR, Noworolski SM, Vigneron DB, Nelson SJ. An automated technique for the quantitative assessment of 3D-MRSI data from patients with glioma. Journal of Magnetic Resonance Imaging. 2001;13(2):167-177. [pmid: 11169821].
McKnight TR, dem Bussche MH, Vigneron DB, Lu Y, Berger MS, McDermott MW, et al. Histopathological validation of a three-dimensional magnetic resonance spectroscopy index as a predictor of tumor presence. Journal of Neurosurgery. 2002;97(4):794-802. [pmid: 12405365].
Meyerand ME, Pipas JM, Mamourian A, Tosteson TD, Dunn JF. Classification of biopsy-confirmed brain tumors using single-voxel MR spectroscopy. AJNR: American Journal of Neuroradiology. 1999;20(1):117-123. [pmid: 9974066].
Moller-Hartmann W, Herminghaus S, Krings T, Marquardt G, Lanfermann H, Pilatus U, et al. Clinical application of proton magnetic resonance spectroscopy in the diagnosis of intracranial mass lesions. Neuroradiology. 2002;44(5):371-381. [pmid: 12012120].
Murphy PS, Dzik-Jurasz AS, Leach MO, Rowland IJ. The effect of Gd-DTPA on T(1)-weighted choline signal in human brain tumours. Magnetic Resonance Imaging. 2002;20(1):127-130. [pmid: 11973038].
Negendank WG, Sauter R, Brown TR, Evelhoch JL, Falini A, Gotsis ED, et al. Proton magnetic resonance spectroscopy in patients with glial tumors: a multicenter study. Journal of Neurosurgery. 1996;84(3):449-458. [pmid: 8609557].
Ng SH, Ko SF, Chen WC, Tang LM, Chang CN, Wai YY, et al. Proton magnetic resonance spectroscopy of cerebral glioma after irradiation. Chang Gung Medical Journal. 2001;24(11):708-716. [pmid: 11820651].
Pirzkall A, McKnight TR, Graves EE, Carol MP, Sneed PK, Wara WW, et al. MR-spectroscopy guided target delineation for high-grade gliomas. International Journal of Radiation Oncology, Biology, Physics. 2001;50(4):915-928.
Pirzkall A, Nelson SJ, McKnight TR, Takahashi MM, Li X, Graves EE, et al. Metabolic imaging of low-grade gliomas with three-dimensional magnetic resonance spectroscopy. International Journal of Radiation Oncology, Biology, Physics. 2002;53(5):1254-1264.
Poptani H, Gupta RK, Jain VK, Roy R, Pandey R. Cystic intracranial mass lesions: possible role of in vivo MR spectroscopy in its differential diagnosis. Magnetic Resonance Imaging. 1995;13(7):1019-1029. [pmid: 8583866].
Poptani H, Gupta RK, Roy R, Pandey R, Jain VK, Chhabra DK. Characterization of intracranial mass lesions with in vivo proton MR spectroscopy. AJNR: American Journal of Neuroradiology. 1995;16(8):1593-1603. [pmid: 7502961].
Preul MC, Caramanos Z, Collins DL, Villemure JG, LeBlanc R, Olivier A, et al. Accurate, noninvasive diagnosis of human brain tumors by using proton magnetic resonance spectroscopy. Nature Medicine. 1996;2(3):323-325.
Preul MC, Caramanos Z, Villemure JG, Shenouda G, LeBlanc R, Langleben A, et al. Using proton magnetic resonance spectroscopic imaging to predict in vivo the response of recurrent malignant gliomas to tamoxifen chemotherapy. Neurosurgery. 2000;46(2):306-318. [pmid: 10690719].
Prost R, Haughton V, Li SJ. Brain tumors: localized H-1 MR spectroscopy at 0.5 T. Radiology. 1997;204(1):235-238. [pmid: 9205253].
Rabinov JD, Lee PL, Barker FG, Louis DN, Harsh GR, Cosgrove GR, et al. In vivo 3-T MR spectroscopy in the distinction of recurrent glioma versus radiation effects: initial experience. Radiology. 2002;225(3):871-879. [pmid: 12461273].
Rand SD, Prost R, Haughton V, Mark L, Strainer J, Johansen J, et al. Accuracy of single-voxel proton MR spectroscopy in distinguishing neoplastic from nonneoplastic brain lesions. AJNR: American Journal of Neuroradiology. 1997;18(9):1695-1704. [pmid: 9367317].
Ricci PE, Pitt A, Keller PJ, Coons SW, Heiserman JE. Effect of voxel position on single-voxel MR spectroscopy findings. AJNR: American Journal of Neuroradiology. 2000;21(2):367-374. [pmid: 10696025].
Rock JP, Hearshen D, Scarpace L, Croteau D, Gutierrez J, Fisher JL, et al. Correlations between magnetic resonance spectroscopy and image-guided histopathology, with special attention to radiation necrosis. Neurosurgery. 2002;51(4):912-919. [pmid: 12234397].
Roser W, Hagberg G, Mader I, Dellas S, Seelig J, Radue EW, et al. Assignment of glial brain tumors in humans by in vivo 1H-magnetic resonance spectroscopy and multidimensional metabolic classification. Magma. 1997;5(3):179-183. [pmid: 9351021].
Schlemmer HP, Bachert P, Herfarth KK, Zuna I, Debus J, van Kaick G. Proton MR spectroscopic evaluation of suspicious brain lesions after stereotactic radiotherapy. AJNR: American Journal of Neuroradiology. 2001;22(7):1316-1324. [pmid: 11498420].
Segebarth CM, Baleriaux DF, Luyten PR, den Hollander JA. Detection of metabolic heterogeneity of human intracranial tumors in vivo by 1H NMR spectroscopic imaging. Magnetic Resonance in Medicine. 1990;13(1):62-76. [pmid: 2319936].
Shimizu H, Kumabe T, Shirane R, Yoshimoto T. Correlation between choline level measured by proton MR spectroscopy and Ki-67 labeling index in gliomas. AJNR: American Journal of Neuroradiology. 2000;21(4):659-665. [pmid: 10782774].
Shimizu H, Kumabe T, Tominaga T, Kayama T, Hara K, Ono Y, et al. Noninvasive evaluation of malignancy of brain tumors with proton MR spectroscopy. AJNR: American Journal of Neuroradiology. 1996;17(4):737-747. [pmid: 8730195].
Shukla-Dave A, Gupta RK, Roy R, Husain N, Paul L, Venkatesh SK, et al. Prospective evaluation of in vivo proton MR spectroscopy in differentiation of similar appearing intracranial cystic lesions. Magnetic Resonance Imaging. 2001;19(1):103-110. [pmid: 11295351].
Sijens PE, Knopp MV, Brunetti A, Wicklow K, Alfano B, Bachert P, et al. 1H MR spectroscopy in patients with metastatic brain tumors: a multicenter study. Magnetic Resonance in Medicine. 1995;33(6):818-826. [pmid: 7651119].
Sijens PE, van den Bent MJ, Nowak PJ, van Dijk P, Oudkerk M. 1H chemical shift imaging reveals loss of brain tumor choline signal after administration of Gd-contrast. Magnetic Resonance in Medicine. 1997;37(2):222-225. [pmid: 9001146].
Sijens PE, Vecht CJ, Levendag PC, van Dijk P, Oudkerk M. Hydrogen magnetic resonance spectroscopy follow-up after radiation therapy of human brain cancer. Unexpected inverse correlation between the changes in tumor choline level and post-gadolinium magnetic resonance imaging contrast. Investigative Radiology. 1995;30(12):738-744. [pmid: 8748188].
Tamiya T, Kinoshita K, Ono Y, Matsumoto K, Furuta T, Ohmoto T. Proton magnetic resonance spectroscopy reflects cellular proliferative activity in astrocytomas. Neuroradiology. 2000;42(5):333-338. [pmid: 10872152].
Tarnawski R, Sokol M, Pieniazek P, Maciejewski B, Walecki J, Miszczyk L, et al. 1H-MRS in vivo predicts the early treatment outcome of postoperative radiotherapy for malignant gliomas. International Journal of Radiation Oncology, Biology, Physics. 2002;52(5):1271-1276.
Tedeschi G, Lundbom N, Raman R, Bonavita S, Duyn JH, Alger JR, et al. Increased choline signal coinciding with malignant degeneration of cerebral gliomas: a serial proton magnetic resonance spectroscopy imaging study. Journal of Neurosurgery. 1997;87(4):516-524. [pmid: 9322842].
Thomsen C, Jensen KE, Achten E, Henriksen O. In vivo magnetic resonance imaging and 31P spectroscopy of large human brain tumours at 1.5 tesla. Acta Radiologica. 1988;29(1):77-82. [pmid: 2831923].
Tien RD, Lai PH, Smith JS, Lazeyras F. Single-voxel proton brain spectroscopy exam (PROBE/SV) in patients with primary brain tumors. AJR American Journal of Roentgenology. 1996;167(1):201-209. [pmid: 8659372].
Tomoi M, Kimura H, Yoshida M, Itoh S, Kawamura Y, Hayashi N, et al. Alterations of lactate (+lipid) concentration in brain tumors with in vivo hydrogen magnetic resonance spectroscopy during radiotherapy. Investigative Radiology. 1997;32(5):288-296. [pmid: 9140749].
Vigneron D, Bollen A, McDermott M, Wald L, Day M, Moyher-Noworolski S, et al. Three-dimensional magnetic resonance spectroscopic imaging of histologically confirmed brain tumors. Magnetic Resonance Imaging. 2001;19(1):89-101. [pmid: 11295350].
Wald LL, Nelson SJ, Day MR, Noworolski SE, Henry RG, Huhn SL, et al. Serial proton magnetic resonance spectroscopy imaging of glioblastoma multiforme after brachytherapy. Journal of Neurosurgery. 1997;87(4):525-534. [pmid: 9322843].
Walecki J, Sokol M, Pieniazek P, Maciejewski B, Tarnawski R, Krupska T, et al. Role of short TE 1H-MR spectroscopy in monitoring of post-operation irradiated patients. European Journal of Radiology. 1999;30(2):154-161. [pmid: 10401596].