# Technical Feasibility Published Proceedings Abstracts

Evidence Table 2 Summary of abstracts examining technical feasibility for magnetic resonance spectroscopy