# Technical Feasibility Published Study Abstracts

Evidence Table 1 Summary of studies examining technical feasibility for magnetic resonance spectroscopy