# CONCLUSION

Human studies conducted on the use of MRS for brain tumors demonstrate that this non-invasive method is technically feasible and suggest potential benefits for some of the proposed indications. There is a paucity of high quality direct evidence demonstrating the impact on diagnostic thinking and therapeutic decision making. In addition, the techniques of acquiring the MRS spectra and interpreting the results are not well standardized. The table below summarizes the current state of evidence.

CATEGORY | DESCRIPTION | EVIDENCE SUMMARY
1 | Technical feasibility and optimization | Large amount of evidence
2 | Diagnostic accuracy
| Distinguish neoplasm from non-neoplasm | Limited evidence
| MRS added to MRI | Limited evidence
| Tumor grading | Limited evidence
| Differentiate intracranial cystic lesions | Limited evidence
3 | Diagnostic thinking impact | Limited evidence
4 | Therapeutic choice impact | Limited evidence
5 | Patient outcome impact | No evidence
6 | Societal impact | No evidence