# SUMMARY

Ninety-six articles met our inclusion criteria for evaluation, with 11 providing information beyond the level of technical feasibility. Eight articles evaluated the test performance of MRS in various settings. Three articles addressed the impact of MRS on diagnostic thinking and therapeutic decision making. No article was found that addressed improvement of patient outcome.

## 5.1 For what metabolite profiles does MRS provide equivalent, complementary, or more accurate diagnostic information?

The following table summarizes the peak intensities and ratios of metabolites evaluated in Category-2 and higher studies.

Category 2 and higher studies that reported metabolite profiles

Study | Category | Qualitative interpretation | Quantitative measurements
Study | Category | Qualitative interpretation | Individual metabolites | | | | | | | Ratios
Study | Category | Qualitative interpretation | Cho | Cr | NAA | Lac | Lip | GI or MI | MGG | Cho/Cr | NAA/Cr | Cho/NAA | NAA/Cho | Lac/Cr | Lip/Cr | Cho/(Lip or Lac) | GI/Cr or MI/Cr | MGG/Cr
Rand | 2 | x
Butzen | 2 | x | x | x | x | x | x | | | | | x
Shukla-Dave | 2 | x
Kimura | 2 | | x | x | x | x | x | | | x | x | | | x | x | x
Moller-Hartmann | 2 | | x | x | x | x | x | | | x | x
Tedeschi | 2 | | x | x | x | x | | | | x | x | | x
Roser | 2 | | x | x | x | | x | x | x | x | x | | | | x | | x | x
Lin (1999) | 3,4 | | x | x | x | x | x | x | | x | x | | | | | | x

These profiles represent a very heterogeneous mix of signals and ratios, study populations, study purpose, and results. Some of the signals and ratios were unique for a particular study. For example, Butzen et al. used a Cho/NAA ratio of greater than 1.0 to classify lesions as tumors for initial diagnosis and reported a sensitivity of 79% and specificity of 77%. No other study used this metabolite ratio; therefore their results could not be verified. The most common ratios evaluated were Cho/Cr and NAA/Cr, which were reported in five studies. With so little data and many questions, the above question could be answered only to a very limited extent.

Cho/Cr is the only metabolite ratio that has been found to be useful in differentiating neoplasm and non-neoplasm and supported by several studies. Among all the full articles examined in this technology assessment, Moller-Hartmann et al. provided the most complete reporting of the metabolite signal intensities and ratios for each type of tumor found in their study population. However, no single metabolite or ratio, other than perhaps a very high Cho/Cr ratio to diagnose PNET, by itself could differentiate among different neoplasms, among different tumor grades, or between neoplastic and non-neoplastic lesions. A moderately high Cho/Cr ratio of approximately four was observed for astrocytoma grade IV and metastases, compared to a value of approximately 1.5 for cerebral infarctions and abscesses. Kimura et al. also reported that a Cho/Cr ratio of 2.48 minimized the rate of misdiagnosis of neoplasm and non-neoplasm. Lin et al. reported that the Cho/Cr ratio was the single most accurate spectral measurement for differentiating neoplastic from non-neoplastic lesions. Unfortunately, the results were presented only as a bar graph.

In the only study that addressed the incremental diagnostic yield, Moller-Hartmann et al. demonstrated that MRS added to conventional MRI improved the number of correct diagnoses and reduced the number of incorrect or equivocal diagnoses.

## 5.2 Does The Use Of MRS Lead To An Improved Net Health Outcome?

Three studies addressed the potential impact of MRS results on diagnostic thinking or therapeutic decision making. Conclusions that can be drawn from these studies are severely limited due to the fact that the two prospective studies had only 15 and 17 patients, respectively, and the only large study was a retrospective analysis of medical records to identify potential opportunities for MRS to influence diagnostic thinking.

## 5.3 Are Voxel Positions And Operator Error Important Factors In Obtaining Diagnostic Images? If So, How Do They Impact MRS Accuracy?

No study explicitly evaluated the impact of voxel position on the accuracy of MRS. The retrospective study by Kimura et al. came closest to this objective. This study evaluated the differences of measurements between the whole lesion and the inner region of the same tumor. Significant differences between the inner region and the whole lesion were found for various types of lesions. Although not specifically reported, the voxel sizes of the inner regions obviously were smaller than those of the whole lesions.

No study commented on the potential impact of operator error in placement of the voxel.

## 5.4 Strengths And Weaknesses Of The Studies

Most of the studies on Proton MRS were Category- 1 studies that addressed technical feasibility. The stated purpose of some of the studies classified as technical feasibility studies was to examine the impact of MRS on practice, but limitations of these studies’ designs kept them from meeting the criteria necessary to achieve that level. Most of the studies we evaluated in categories 2 to 4 concluded that MRS has value for the indications studied. One study (Rand et al. 1997), which measured the accuracy of single-voxel, image-guided proton MRS in distinguishing normal from abnormal brain tissue and neoplastic from non-neoplastic brain disease, was an excellent example in some respects of the type of study needed to assess diagnostic efficacy. The use of multiple blinded readers and ROC analyses should be encouraged. Detailed presentation of quantified spectra intensities and ratios similar to those reported in the article by Moller-Hartmann et al. would help the interpretation of results across studies.

Sample size is also an important limitation. Sample sizes that might be adequate for investigating one type of tumor are not necessarily adequate for investigating multiple types of tumors in the same study. This applies to tumor grades as well.

In summary, while there are a large number of studies that confirm MRS’ technical feasibility, there are very few published studies to evaluate the diagnostic accuracy and whether it can positively affect diagnostic thinking and therapeutic choice. Those studies that do address these areas often have significant design flaws including inadequate sample size, retrospective design and other limitations that could bias the results.

## 5.5 Implications for future research

The relative rarity of brain tumors, the relatively low installed base of MRS software and the constraints of clinical practice have precluded the establishment of large, double-blinded controlled trials that would go beyond exploring technical feasibility. Experience with MRS has only become available to the general community of radiologists within the past five years. Prior to this time, commercial software for shimming and analyzing spectra was not reliable, except in the hands of trained specialists. The current commercial software is vastly improved and can be mastered with a reasonable amount of additional training. Prior to about 1995, MRS was available at only a few research-oriented institutions. Hence studies were typically single institution feasibility studies or small case series. The recent change in the availability of MRS is only now reaching enough centers to allow more advanced investigations using the technique. MRS is still not available in many community hospitals, and even some academic centers.

The reason that the research is not more advanced may be that in addition to the relatively recent availability of MRS, its use in brain tumor evaluation evolved by using techniques that were not straightforward. Initially, it was hoped that tumors would have a characteristic “signature” that would allow rapid MRS diagnoses. Because the sensitivity of MRS allows demonstration of only a limited set of chemical compounds in the brain, such signatures have not been found. However, means of using the chemical information that is provided by MRS for tumor evaluation has progressed as new ideas have evolved for effective use of this information.