# RESULTS: Proceedings Abstracts

As described above, abstracts and proceedings from following professional societies for the years 2001 and 2002 were reviewed:

- ASNR-American Society of Neuroradiology
- RSNA-Radiological Society of North American
- ISMRM-International Society for Magnetic Resonance in Medicine

Because these were abstracts and not full papers, data on basic study design information such as patient gender and means of enrolling patients were frequently unavailable. Of the 241 proceedings-generated abstracts reviewed, 44 were provided information beyond the technical feasibility category. The following table summarizes the distribution of abstracts by category:

CATE- GORY | DESCRIPTION | (#/%)
1 | Technical feasibility and optimization | 44
2 | Diagnostic accuracy | 8^*^
3 | Diagnostic thinking impact | 1
4 | Therapeutic choice impact | 0
5 | Patient outcome impact | 0
6 | Societal impact | 0

* One study shown in this category could also be considered a Category-3 study.

## 4.1 Category-1 Abstracts: Technical Feasibility

Evidence Table 2 shows selected characteristics of the 44 technical feasibility (Category 1) abstracts. Similar to Evidence Table 1 containing technical feasibility studies, it summarizes: year of publication, country in which the research was conducted, study characteristics including number of diseased (cases) and non-diseased (control) patients, method of patient enrollment, diagnostic status, and age. The table also shows the size of the volume of tissue (voxel) of interest as well as whether single or multiple voxel sampling was used. Finally, the table indicates the principal clinical study objectives: tumor differentiation, tumor grading, distinguishing primary tumor tissue from recurrent tumor and from metastases, and identifying necrotic tissue. In addition, there were two instances where there were duplicate abstracts for the same studies from different proceedings.

There were forty-seven abstracts reviewed for Category 1 from 3 different proceedings for 2001 and 2002. Forty-four unique studies remained after removing four duplicate studies. In addition, there were a minimum of four instances of overlapping population represented in the abstracts. The abstracts reported on 1,445 patients. One study reported on 174 diagnostic ‘studies’ without mentioning the number of patients and one reported the results of 14 ‘studies’. Twenty studies (42.5%) were from the US. The ages of patients described in eight of the abstracts varied considerably; ranging was from 8 to 84 years. As in the complete studies reviewed, we excluded abstracts that were predominantly pediatric.

Five studies were reported as prospective and five were retrospective. The remaining abstracts reported no data on study design. The largest sample reported in an abstract was 130 patients. Most abstracts did not include controls. Single voxel and multiple voxel sampling were used approximately equally. In six studies no voxel data were reported and in four a combination of both approaches were employed.

Tumor differentiation (14 studies) and grading (10 studies) were the most frequently cited clinical objectives. Other clinical objectives varied widely such as characterization of metabolite ratios (six abstracts), prognosis (two abstracts), measure of lipid levels (two abstracts), and tumor response to treatment (two abstracts).

## 4.2 Category-2: Studies that Evaluate Test Performance

The proceedings abstracts described eight studies in this category. Studies in this category could be further grouped into studies with the main purpose of differentiating tumors from non-tumors, grading of tumors, differentiating intracranial cystic lesions, and to assess the incremental value of MRS added to MRI.

### 4.2.1 Abstracts of Category-2 Studies Differentiating Neoplasm from Non-neoplasm

Yin et al. (2002) evaluated 40 lesions in 35 patients with suspected brain neoplasms or recurrent neoplasm. The purpose of this study was to measure the accuracy of multivoxel 3D MRS proton MRS in distinguishing neoplastic from non-neoplastic brain lesions (blinded vs. unblinded). Final diagnoses were assessed by clinical examination, biopsy and serial MRI.

The specificity for distinguishing between neoplastic and non-neoplastic lesions was 88.6%. Of the 35 cases, 21 had neoplasms and 19 had non-neoplastic lesions. Of 16 glioma, 14 were correctly identified through increased Cho and decreased NAA for the gliomas. The metabolic profiles of the following types of tissue were studied: abscess (increased Lac), metastasis (increased Cho and Lac and no NAA peak), demyelinating lesion (decreased NAA and normal Cho), lymphoma (high Cho and lipids), and necrosis (high Cho and decreased metabolism). There was also little diversity of lesions, no information about patient ages, no statistical analysis, and no comparative data. The study did, however, report a form of blinding, but no detail was provided.

Herminghaus et al. (2002a) evaluated 293 consecutive patients diagnosed with focal brain lesions. The purpose of this study was to assess the potential of single voxel MRS (1.5 T Siemens Magnetom Vision) to differentiate between neoplastic and non-neoplastic lesions, between high grade tumors and metastases or lymphomas, and between different types of tumors. The authors studied 25 types of lesions.

Discriminant analysis was used to “confirm significance” of differences between clusters formed by the authors. The analysis yelded five clusters: one containing glioblastoma (unknown grade), gliosarcoma, and embryonal tumors (IV WHO). A second cluster included anaplastic astrocytomas, anaplastic oligoastrocytomas, anaplastic oligodendrogliomas, anaplastic meningeoma (WHO III), and lymphomas. The third cluster included glial low grade tumors, gangliogliomas, gangliocytomas, neurominomas, and glioses and abscesses. The fourth cluster contained tumor necrosis, tumor cysts, infectious cysts, and meningeomas. The fifth cluster contained metastasis, glioblastoma, gliosarcoma, and embryonal tumor grade IV WHO. The authors concluded that MRS can be helpful in differentiating:

- Low grade from high grade tumors
- Metastasis and lymphomas from benign or low grade tumors
- Abscesses from gliobastoma and meastasis
- Silent infarct from low grade tumors
- Tumor cysts, infectious cysts, and necrotic tissue from each other and from other lesions
- WHO I/II meningeomas from metastasis

The authors concluded MRS could not distinguish:

- Between different tumor types of the same grade.
- Lymphomas from grade III tumors
- Metastasis from glioblastoma
- Low grade brain tumors from gliosis

“Success rates” were reported for the above classifications, but the level of detail provided in the abstract is insufficient for meaningful interpretation of these statistics. Finally, the fact that this study did not describe the standard against which the focal brain tumors were diagnosed, makes its difficult to interpret its conclusions.

### 4.2.2 Abstracts of Category-2 Studies Detecting Tumor Recurrence

Kovanlikaya et al. (2002) prospectively examined 16 lesions in seven men and seven women (mean age 50 yrs) to determine the value of multi-voxel MRS (1.5 T; 1 cm^3^ spatial resolution) of glial neoplasms in detecting tumor recurrence after treatment with surgical excision, radiotherapy, and chemotherapy. The neoplasms included 12 astrocytomas, one oligodendroglioma and three mixed tumors of Grade II (5), Grade III (5) and Grade IV (6). Voxels showing the highest choline levels were analyzed for levels of NAA, creatine and lactate/lipid values and compared to the matched contralateral normal side of the brain. The results were assessed pathologically (6 lesions) and clinically (10 lesions).

Tumor recurrence was observed in eight of the 14 patients. Choline levels were much higher (114% elevation) in the recurrent lesions, with much lower levels in stable patients (7% depression). Choline elevation had a high sensitivity for detecting tumor recurrence (100%; positive predictive value = 82%). The specificity of choline depression for detecting stability was 72% (negative predictive value = 100%.) The authors, despite the small numbers, also suggested that the lactate/lipid peak in three patients was highly specific for detecting necrosis but not sensitive for detecting recurrence. There was no independent verification of the results.

Lefkowitz et al. (2002) prospectively examined 27 lesions in 22 patients whose brain tumors had been surgically excised and/or irradiated to evaluate MRS’ usefulness for diagnosing recurrent neoplasms. Single and multivoxel MRS was used to obtain maps of NAA and Cho concentration, ratio maps of Cho/Cr peak areas and heights, and tables of Cho/Cr ratios to identify potential tumor-containing voxels. A Cho/Cr ratio greater than or equal to 2.0, behavior of control voxels, and other spectral features were considered for tumor/non-tumor designations. Biopsy or follow-up imaging was used to confirm tumor status.

For the 27 MRS results, there were 19 gliomas, five metastases, two lymphomas, and one medulloblastoma. Sensitivity for detecting tumor recurrence was 89% (positive predictive value = 73%). Specificity was 33% (negative predictive value = 60%). Overall accuracy was 70%. Tests of statistical significance and confidence intervals were not reported. There was no independent verification of results.

Shah et al. (2002) assessed how well MRS performed in identifying tumor recurrence compared to SPECT and CT/MRI. These authors studied nine patients who had undergone surgery and radiotherapy or radiotherapy alone for an average of 28 months with tumors suspected of recurrence. The tumors comprised: oligodendroglioma II (two); oligodendroglioma III (one); anaplastic astrocytoma (two); malignant mixed glioma (one); astrocytoma II (two); and glioblastoma multiforme (one). Choline spectra derived from MRS (1.5 T Siemens) sequence voxels ranging from 1.3 ml to 3.8 ml were used as markers for recurrence and were compared with radiological and SPECT results.

The kappa (k) measure of agreement was calculated between MRS and each of the other two tests. The results were: MRS vs. SPECT (k=0.72), MRS vs. CT/MRI (k=0.57) and CT/MRI vs. SPECT (k=0.37). There was no biopsy confirmation of tumor recurrence and therefore no ‘reference standard’. In addition, the sample size was small, and no tests of statistical significance or confidence intervals were reported.

Lichy et al. (2002) examined the value of MRS, FDG-PET, and IMT-SPECT in evaluating suspicious brain lesions detected by MRI follow-up of 24 patients with irradiated gliomas. Multivoxel 2D MRS (1.5 T; voxel size = 8.8 × 8.8 ×15 mm^3^) was used to obtain relative signal intensity ratios of Cho, Cr, and NAA. Eighty-six voxels from suspicious lesions and 147 from ‘normal’ areas were analyzed. Clinical and MRI/CT follow-up, not biopsy, was used to classify lesions as neoplastic or non-neoplastic.

This study reported that the true positive rate (it is assumed that surgery was the standard of comparison) for identifying neoplastic tissue was 88% for MRS, 73% for FDG-PET, and 100% for IMT-SPECT. The true positive rate for identifying non-neoplastic tissue was 89% for MRS, 100% for FDG-PET and 75% for IMT-SPECT. Cho and Cho/NAA were present in significantly higher levels in neoplastic tissue. Additional information about sensitivity and specificity were reported, but the performance outcomes being evaluated were unclear. In this study three diagnostic techniques were compared only to each other and not to either biopsy or surgical results. In addition, there was no independent verification of results, and no confidence intervals for diagnostic test performance were reported.

### 4.2.3 Abstracts Of Category-2 Studies Distinguishing Homogeneity, Proliferation, And Grade Of Lesions

Herminghaus et al. (2001a) prior to biopsy evaluated 29 consecutive patients with MRI results and history suggestive of neuroepithelial brain tumors. The purpose of the study was to evaluate MRI’s ability to distinguish low from high-grade tumors. Single voxel MRS (1.5 T) was used to evaluate tumor tissues as well as normal appearing brain tissue in the contralateral hemisphere. NAA, total creatine, Cho, Lip, and Lac were analyzed. Tumor spectroscopic data were classified (“observer-independently”) as grade I/II or III/IV according to the World Health Organization system. Biopsies were performed and confirmed by following patients for three years. Tumors showing at least 6 months of stability were defined as low-grade; those tumors showing progression were classified as high-grade.

While the authors reported sensitivity (100%), specificity (86%), and overall accuracy (96%), it is not clear what the reference standard was. Since the authors also report sensitivity (95%), specificity (86%), and overall accuracy (93%) for biopsy, it may be inferred that biopsy was not the reference standard. It is possible that surgery was the reference standard, but the study does not mention whether or how frequently surgery was performed. This ambiguity makes it difficult to assess the meaning of these findings. In addition, there was no independent verification of results. (This study might also be classified as Category 3).

## 4.3.1 Abstracts of Category-3: Studies Conducted to Evaluate Diagnostic Thinking Impact

Mao et al., (2002) evaluated the utility of single voxel MRS (1.5 T Phillips NT scanner) to guide selection of biopsy target areas in eight patients with a previous biopsy yielding equivocal results. This study might be considered as providing information for thinking about diagnostic impact. Areas of decreased NAA and elevated Cho and Lac were identified so that NAA and Cho maps could be used to target these areas as potential biopsy sites. The maps were superimposed on the stereotactic anatomical image to develop coordinates for the sites. Biopsies were then performed, followed by either CT or MRI.

MRS results showed abnormal metabolite maps for all eight patients, with seven showing decreased NAA and increased CHO. Biopsy sites were chosen from areas showing the most elevated CHO levels, and the biopsies were positive for seven of the eight patients. Tumor types included: two anaplastic astrocytomas (III); glioblastoma multiforme (IV); two infiltrative astrocytomas (II); oligodendroglioma (II).

While the study described in this abstract shows the technical feasibility of using MRI to help select the site of biopsy, the sample size of eight was small, with no statistical analysis (it mentions a ‘significant’ decrease in NAA and increased CHO, but no quantitative data to support this is presented in the abstract). In addition, there was no comparison group of patients with non-MRS guided biopsy and there was no independent verification of the results.