# RESULTS: Full Published Studies

The following table shows the number of studies in each of the categories. After reviewing the 959 abstracts and 137 retrieved articles, 75 studies were classified as Category-1 Technical feasibility studies. Ten studies were identified as providing information beyond that of the technical feasibility category. An additional 10 studies were added to Category- 1 and 1 study added to Category- 2 from references given by peer reviewers of the draft version of this report. In this section we report on the 96 published full-length studies classified using the approach described above. There were eight articles for Category-2, two articles for Category-3 (one study also qualify for Category-4), two articles for Category- 4 (one article shared with Category-3), and none for Category- 5 or Category- 6. Nearly all the studies identified were in Categories- 1 and 2, with the vast majority in Category- 1. The following table summarizes these results:

CATEGORY | DESCRIPTION | #
1 | Technical feasibility and optimization | 85
2 | Diagnostic accuracy | 8
3 | Diagnostic thinking impact | 2^*^
4 | Therapeutic choice impact | 2^*^
5 | Patient outcome impact | 0
6 | Societal impact | 0

* One study overlapped Category- 3 and Category- 4.

## 3.1 Category- 1 studies: Technical Feasibility

Evidence Table 1 shows selected characteristics of the technical feasibility (Category- 1) studies. Included in this table are the year of publication, country in which the research was conducted, study characteristics including number of diseased (case) and non-diseased (control) patients, method of patient enrollment, diagnostic status, and age. The table also shows the size of the volume of tissue (voxel) of interest as well as whether single or multiple voxel sampling was used. Finally, the table indicates the principal clinical study objectives: tumor differentiation, tumor grading, distinguishing primary tumor tissue from recurrent tumor and from metastases, and identifying necrotic tissue.

We reviewed 85 Category- 1 studies published from 1988 through 2003 involving approximately 2434 patients; fifty (59%) of the studies were published before 2000. There was extensive international representation in these studies. Twenty-four (28%) were from the US, 15 (18%) were from Japan, and 19 other countries were represented. The ages of patients included in the studies varied considerably; the range was from 1– 88 years, but we excluded studies that consisted predominantly of pediatric patients.

Almost all of the studies were prospective, with several retrospective and several of unknown design. The largest study included 120 cases. Many of the studies did not include control patients; for those studies that did, however, the maximum number of healthy controls was 151. One study reported approximately 300 diagnostic studies of controls. The mechanism used to enroll patients was generally not reported. In almost all of the studies, the disease status of the participants was ascertained via biopsy, although in a few instances the ascertainment was via clinical assessment only.

Single voxel sampling was the predominant methodology, although multiple sampling was also often used, and a combination of the two approaches was sometimes employed. In some articles the technique was not reported. Voxel volumes ranged widely.

Tumor differentiation (36 studies) and grading (30 studies) were the most frequently cited clinical objectives. Identifying necrotic tissue (15 studies) was also a frequent objective. Distinguishing metastases from primary tumors (5 studies) and recurrent from primary tumors (four studies) were less frequent objectives.

While not shown in the table, nearly all of these studies reported that metabolite peaks were obtained and metabolite ratios calculated. The authors analyzed spectral patterns using these measures.

## 3.2 Category-2: Studies that Evaluate Test Performance

Eleven studies were identified as providing information beyond the technical feasibility category. There were eight articles for Category-2, two articles for Category-3 (one study also qualify for Category-4), two articles for Category-4 (one article shared with Category-3), and none for Category-5 or Category-6.

A total of eight studies provided data for Category-2. Studies in this category could be further grouped into studies with the main purpose of differentiating tumors from non-tumors (three), grading of tumors (two), differentiating intracranial cystic lesions (one), and assessing the incremental value of MRS added to MRI (one). The purposes of the studies within the same group were sufficiently different so that combining or comparing studies within the same group was infeasible.

One group of investigators from the Medical College of Wisconsin published three articles (Rand et al., 1997; Adamson et al., 1998; Butzen et al., 2000) using overlapping patient samples but addressing different research issues. Fifty-five MRS spectra belonging to 53 patients in the 1997 article were included in the 99 MRS spectra evaluated in the 2000 article. The study by Adamson et al. (1998) was a retrospective analysis of 78 patients from the same study population and is discussed under the Category-4 section.

### 3.2.1 Studies Differentiating Neoplasm from Non-neoplasm

Rand et al. (1997) evaluated 55 brain lesions in a consecutive series of 53 patients between September 1994 and December 1995. The patients included 31 males and 22 females between the ages of 14 and 81 years (mean 45 years), and they had suspected brain neoplasm or recurrent neoplasia. The purpose of the study was to measure the accuracy of single-voxel, image-guided proton MRS in distinguishing normal from abnormal brain tissue and neoplastic from non-neoplastic brain disease.

Using voxel sizes of 1 to 3 cm^3^, MRS spectra were obtained using a clinical 0.5 Tesla MR system (manufacturer not stated) with a prototype head coil or a receive-only conformal surface coil. The voxel was centered over solid portions of the lesion and avoided necrotic debris or edema.

Spectra were interpreted by visual inspection. At the time of MRS, one of the four neuroradiologists and one MR spectroscopist prospectively wrote a formal report using available clinical data and imaging studies. The unblinded readers interpreted the spectra as diagnostic or not, and if diagnostic, as neoplasia or non-neoplasia. Four neuroradiologists blinded to the clinical data and MRI results interpreted spectra retrospectively. The blinded readers classified the spectra as diagnostic or not, if diagnostic as normal or abnormal, and when abnormal as neoplasia or non-neoplasia.

For blinded interpretations, control and patient spectra were presented in random order. Blinded readers interpreted the results independently. Additional measures were taken to minimize biases in the interpretation of results.

The blinded readers rated the spectra from one to 100 as normal or abnormal, and as neoplastic or non-neoplastic, respectively. For the purpose of estimating test performance, a score of less than 50 was defined as negative (normal or non-neoplastic), a score of 50 and above was defined as positive (abnormal or neoplastic). The full range of the scores from each reader was used to create receiver operating characteristic (ROC) curves.

Sensitivity, specificity, positive predictive value, negative predictive value, and accuracy were calculated for the unblinded reader and each blinded reader for untreated patients and treated patients separately.

Spectra from 55 brain lesions in 53 patients were included in the analysis. In two patients, two lesions were studied. Fourteen patients (15 lesions) had received treatments for brain neoplasia before undergoing MRS. Histological diagnoses were available for 50 lesions. Diagnoses were established in three cases of infarcts by clinical follow-up and serial radiologic studies (CT, MRI, MR angiography, catheter angiography, or a combination) in which the lesions diminished in size. Diagnoses were established in two cases of acute demyelinating disease by clinical follow-up and reduction of lesion size on serial MRI.

The distribution of 42 neoplasia final diagnoses included: one astrocytoma-not otherwise specified, four astrocytoma grade I, four astrocytoma grade II, two astrocytoma grade III, 10 astrocytoma grade IV – one glioblastoma multiforme, one giant cell astrocytoma, one oligodendroglioma, four mixed glioma, one ganglioglioma, one ependymoma, six meningioma, four metastases, and two dysembryoblastic neuroepithelial tumor. The distribution of 13 non-neoplasia final diagnoses included: one Rathke’s pouch cyst, three infarct, one parasitic infection, one sarcoidosis, one acute inflammation and gliosis, two demyelinating disease, one radiation necrosis without neoplasm, one vasculitis, one arteriovenous malformation with old hemorrhage, and one neuroglial (gyral) dysplasia.

Blinded readers disqualified 20 (9%) of 213 patient spectra as non-diagnostic because of unacceptably low signal to noise ratios, ambiguous resonance assignments, unacceptably broad resonances, lack of detectable metabolite resonance, equivocal findings of neoplasm versus non-neoplasm, or a combination of the above.

Unblinded readers produced 40 true-positive, 12 true-negative, no false-positive, and two false-negative diagnoses. One spectrum was interpreted as nondiagnostic. Compared to the reference standard, the sensitivity, specificity, PPV, NPV, and accuracy of MRS to distinguish between neoplastic and non-neoplastic spectra for the unblinded readers were 0.95, 1.00, 1.00, 0.86, and 0.96, respectively.

Compared to the reference standard, the four blinded readers accumulated 12 false-positive interpretations on eight spectra and 22 false-negative interpretations on 13 spectra. The sensitivity, specificity, PPV, NPV, and accuracy of MRS to distinguish between neoplastic and non-neoplastic spectra for the four blinded readers averaged 0.85, 0.74, 0.92, 0.61, and 0.83, respectively. The test performance showed better results when only untreated patients were analyzed.

This study was exemplary for many aspects in this category. This was a prospective study and included a variety of diagnoses, used ROC analysis and multiple blinded readers to interpret the spectra results, and used well-defined reference standards and methods to minimize bias. The number of patients with and without neoplasm and the number of diagnoses was relatively small, however. The lack of a quantitative analysis of the MRS spectra profile also diminishes the ability to compare their results with other studies.

The population studied by Butzen et al. (2000) from the Medical College of Wisconsin is a superset of the patient population studied by Rand et al. in 1997. The purpose of this study was to compare a logistic regression (LR) model with blinded and unblinded qualitative MRS interpretations for the discrimination of neoplastic from non-neoplastic brain lesions using MRI-guided single voxel proton MRS data. The MR system and technique used were described in the paper by Rand et al. Ninety-nine consecutive patient spectra (the number of patients was not reported) with suspected brain neoplasms or recurrent neoplasia referred for MRS were evaluated by the LR model, of which 55 were evaluated by Rand et al. in the earlier study.

The LR model computed the probability of neoplasm ranging from zero to one. A cutoff probability of 0.8 for a positive MRS examination for neoplasia was determined by adjusting the cutoff to obtain equal rates of false-negative and false-positive results. Qualitative interpretations were made by two blinded neurologists and by one of five unblinded staff neuroradiologists and one staff spectroscopist.

The LR model was applied to 99 spectra with a sensitivity of 87% and a specificity of 85%. One blinded reader evaluated 86 spectra with a sensitivity of 75% and a specificity of 90%. The second blinded reader evaluated 90 spectra with a sensitivity of 88% and a specificity of 58%. The unblinded reader evaluated 95 spectra with a sensitivity of 89% and a specificity of 92%. The results of the blinded and unblinded readers were similar to those in the earlier study. Using a threshold of greater than one for the metabolite ratio Cho/NAA (NAA = N-acetylated compounds) to classify tumors, the sensitivity for 99 spectra was 79% and the specificity was 77%.

McKnight et al. (2002) tested a statistical index derived from a linear model of choline vs. NAA for discriminating neoplastic from non-neoplastic brain lesions. A subset of 26 patients in this study with high grade tumors were also reported on by Pirzkall et al. in a Category-1 study. Multi-voxel (1 cm^3^) 3D-MRSI was performed with a 1.5 Tesla General Electric Medical Systems Signa scanner (General Electric Medical Systems, Signa; Milwaukee, WI) on 68 patients (ages unknown) with suspected gliomas. The statistical model yielded an MRS-derived score (Cho-NAA Index—the “CNI”) summarizing the degree of difference between relative Cho and NAA levels in a specific voxel and that of a population of control voxels for each patient.

Of the original 68 patients, biopsies revealed that 26 had Grade II gliomas, 26 had Grade III gliomas, and 16 had Grade IV gliomas. Only 44 patients gave consent for their surgeons to be guided during the biopsy by MRS-guided instructions to sample four voxels --- one each with a high CNI score, one with a low score and two with intermediate values. (The remaining 24 patients’ MR images and CNI scores were used in another analysis of the distribution of metabolic abnormality with hyper intense lesions on T_2_-weighted MR images and contrast-enhancing lesions.)

The one hundred biopsy samples from the 44 patients yielded the following histological classification of gliomas: Grade II: 36; Grade III: 34; and Grade IV: 23. Seven of the samples were nontumorous. The patient-level distribution of gliomas was: Grade II: 12; Grade III: 21; and Grade IV: 11. None of the patients were tumor-free.

The difference between CNIs of tumor and non-tumorous samples was highly significant. An analysis to assess the ability of the CNI to differentiate between tumor and non-tumorous samples yielded an ROC area of .94. With a CNI cutoff of 2.5, the sensitivity of this test was 90% and the specificity was 86%. The 95% bootstrap confidence interval for the sensitivity was 84 –96% and for specificity was 56–100%. These sensitivities were tumor-level, not patient-level.

This study also used the MRS CNI methodology to examine the proportion of patients of all 66 patients with evidence of tumor outside the area of contrast enhancement. Regardless of tumor grade, 41–45% of hyperintense lesions showed metabolic evidence of tumor (CNI >2.5), and 36–45% of non-enhancing lesions also showed such evidence.

Finally, a sub-analysis analyzed grade. There were 7 tumors with heterogeneous histological findings; in three of these cases, the CNIs did not correlate with the histological grade.

This study had several limitations. The authors do not describe how patients were enrolled in the study, nor was the analysis of MRS results blinded to final diagnosis. The small number of non-tumorous samples limited statistical power, and the restriction of tumors to gliomas limited generalizability. There may have been bias due to the number of dropouts.

Kimura et al. (2001) retrospectively evaluated the accuracy of single-voxel MRS spectra in patients with ring-like enhanced lesion using gadolinium-enhanced MRI. Forty-five patients including 29 men and 16 women between the ages of 26 to 75 years with various brain lesions were studied. The diagnoses included 19 metastases, 10 glioblastoma, seven radiation necrosis, five brain abscesses, and four cerebral infarctions.

MRS was performed with a 1.5 Tesla Signa Horizon System (GE Medical System, Milwaukee, WI). The investigators evaluated two types of volume of interest (VOI). One VOI was selected to include the whole ring-like enhanced rim and the central region of the lesion (whole lesion). The second type of VOI was selected to include only the non-enhanced inner region. The size of the voxel was not reported in the article. Quantitative analyses of spectra were performed on Cho, Cr, NAA, Lac, and Lip signals (Cho = choline; Cr = total creatine; NAA = N-acetylated compounds; Lac=lactate; Lip = lipids, protein, and lactate). Three metabolite ratios (Cho/Cr, Lac/Cr, NAA/Cr) were calculated and used for analyses.

For the whole lesions, the mean Cho/Cr ratio of metastases was 4.56 and 4.12 for glioblastoma. The mean Cho/Cr ratio for radiation necrosis was 2.33 and 1.48 for cerebral infarction. Significant differences were found for: metastases and radiation necrosis, metastases and cerebral infarction, and glioblastoma and cerebral infarction. Significant differences in the Cho/Cr ratios between the whole lesion and inner region were found in the spectra of metastases and glioblastoma. There were no significant differences among the lesion types for the Cho/Cr ratios in the inner region.

The investigators found that using a Cho/Cr ratio of 2.48 for the whole lesion, the lowest rate of misdiagnosis was achieved in differentiating neoplasm from non-neoplasm. The positive predictive value using this threshold for metastatic brain tumors and glioblastoma was 89% (95% CI, 65 – 99%) and 60% (95% CI, 26 – 88%), respectively. The positive predictive value of a Cho/Cr ratio of less than 2.48 for diagnosing radiation necrosis and cerebral infarction were 71% (95% CI, 29 – 96%) and 100% (95% CI, 40 – 100%), respectively.

The lowest rate of misdiagnosis in differentiating metastases and radiation necrosis was achieved using a Cho/(Lip or Lac) ratio of 0.3 for the whole lesion. The positive predictive value of using a threshold value of greater than 0.3 to diagnose metastases was 94% (95% CI, 73 – 99%). The positive predictive value of using a threshold value of less than 0.3 to diagnose radiation necrosis was 100% (95% CI, 59 – 100%).

The relatively small sample size, narrow spectrum of brain lesions, and retrospective nature of this study limited the generalizability of this study. In addition, abscesses were excluded from the analyses.

### 3.2.2 Clinical Utility of MRS added to MRI

Moller-Hartman et al. (2002) evaluated the clinical utility of MRS added to MRI for the differentiation of intracranial neoplastic and non-neoplastic mass lesions. The study population consisted of a consecutive series of 176 patients presented to the neuroradiology department with focal intracranial mass lesions following MRI and/or CT imaging. Spectroscopic studies were performed using a 1.5 Tesla whole-body MR scanner (Magnetom Vision, Siemens). All patients underwent a single voxel MRS with a mean voxel volume of 8 cm^3^ (range 4 – 12 cm^3^). The voxel was placed in the solid part of the lesion excluding necrotic or cystic tumor parts or adjacent edematous areas. An acceptable voxel had to contain at least an estimated 70 percent tumor tissue. Whenever feasible, a reference spectrum of the same voxel size was acquired in the homologous region in the contralateral brain.

Within 10 days of MRS, histological diagnosis was obtained by stereotactic biopsy or craniotomy and open biopsy, except in nine (of 25) cases of brain abscesses or focal inflammatory brain disease and nine (of nine) cases of cerebral infarction. Features on MRI or CT, clinical course, cerebrospinal fluid findings, and blood tests made the final diagnoses of the non-biopsied cases. Twelve out of the 176 spectra were of poor quality and were excluded from further evaluation. Final diagnoses for the remaining 164 interpretable spectra included 23 low-grade astrocytomas, 28 anaplastic astrocytomas, 39 glioblastomas, four PNETs or medulloblastomas, 18 metastases,nine meningiomas, nine neurinomas, 25 cerebral abscesses and nine brain infarctions.

Two neuroradiologists independently reviewed the combined MRI and MRS results blinded to the final diagnoses and two other neuroradiologists independently reviewed only the MRI results blinded to the final diagnoses. A diagnosis was classified as “correct” if the reader correctly assigned the case to the type of intracranial mass lesion and the tumor grade, according to the WHO classification of the final diagnoses. A “no evidence diagnosis” was assigned if the neuroradiologist could not decide between several diagnoses. The article did not report whether the two neuroradiologists read all the images or spectra in the same group or how discrepancies between the readers were resolved.

Tumor metabolite signal intensities were expressed as the percentage of the corresponding metabolites of the reference spectrum using measurements of the peak area signal intensity of each metabolite (NAA, Cr, and Cho) in the lesion. Two metabolite ratios (Cho/Cr and NAA/Cr) were also calculated.

Compared with the reference spectrum on the contralateral side of the brain, the Cr level was about 75–80% among the gliomas and there were no significant differences between the different tumor grades. The levels of Cr in the metastases, abscesses, and infarctions were about 40–50%, compared to the reference. The Cho levels decreased to 70–80% in infarctions and abscesses, and increased in metastases, PNET, and gliomas. The Cho level progressively increased with the tumor grade. The Cho/Cr ratios were: infarction = 1.45; astrocytoma I = 1.33; astrocytoma II = 2.13; astrocytoma IV = 3.93; PNET = 18.4; metastases = 3.97; abscesses = 1.52; meningioma = 4.81; neurinoma = 3.08.

Of the 176 spectra, conventional MRI alone made 97 (55.1%) correct diagnoses, 27 (15.3%) incorrect diagnoses, 52 (29.6%) no evidence diagnoses, and no examinations without diagnostic value. MRS added to MRI produced 124 (70.5%) correct diagnoses, 16 (9.1%) incorrect diagnoses, 24 (13.6%) no evidence diagnoses, and 12 (6.8%) examinations without diagnostic value. There was no case in which a correct diagnosis made by MRI alone was interpreted incorrectly by the combination of MRI and MRS.

### 3.2.3 Studies on Tumor Grading

Roser et al. (1997) prospectively evaluated 35 MRS spectra in 17 patients with suspected glial brain tumors. The purpose of the study was “to apply the metabolic features found in a previous study of 21 healthy controls and humans with gliomas to a new cohort of patients with a suspected glial brain tumor and other healthy volunteers.” The age and sex of the patient population were not reported. None of the patients had received stereotactic biopsy, open surgery, or radiation therapy before MRS. Sterotactic biopsy or open surgery was performed within a few days after MRS.

MRS spectra of single-voxel size 8 cm^3^ were acquired using a 1.5 Tesla MR system (Siemens Magnetom SP 400, Siemens Medical Systems, Erlangen, Germany). The VOI was placed as close as possible to the tumor center and covered at least 75% of the tumor tissue.

Using “training” data from an earlier study of 21 healthy controls and patients with gliomas, the investigators calculated five ratios (NAA/Cr, MGG/Cr, Cho/Cr, GI/Cr, Lip/Cr) using 6 metabolite resonance measurements (NAA = N-acetylated compounds; Cr = total creatine; MGG = macromolecules, glutamine, and glutamate; Cho = choline; GI = glycine and myo-inositol; Lip = lipids, protein, and lactate). These five metabolite ratios were used in an orthonormal discriminant vector (ODV) analysis (Kauppinen et al., 1993) to construct a graph of two-dimensional metabolite space. The two axes were the ODV results based on a linear combination of the five metabolite ratios. By plotting the two ODV results of the metabolite ratios of individual patients from the training data, different tumor grades and healthy controls occupy distinct regions in the graph that could be classified as high grade, low grade and healthy volunteers.

In the validation study, the correlation of superimposing new patients’ data onto the classification derived from the training data was noted. Histological diagnoses of the new patients included ten glioblastoma multiforme, two astrocytoma grade III, and five astrocytoma grade II. All ten cases of glioblastoma multiforme were in the proximity of the high grade region defined by the training data. Four of five astrocytoma grade II were classified as low grade gliomas, and one was classified as high grade. One of the two astrocytoma grade III was classified as high grade and the other as low grade. In addition, the contralateral normal-appearing matter of tumor patients was assigned as normal in six cases and low grade in two cases.

The results of this study cannot readily be generalized. Only 21 healthy subjects and patients with glial brain tumor were selected in the development of the ODV equations. In the prospective validation study, all 17 patients also had glial brain tumors; thus the results of this study cannot be generalized to populations with a broader spectrum of brain lesions. A much larger number of patients with a broader spectrum of brain lesions is needed to develop the diagnostic criteria and to verify the results.

Tedeschi et al. (1997) prospectively studied 27 patients with known brain gliomas to test the hypothesis that MRS can help detect malignant degeneration and/or recurrence (progressions). The 27 patients received from two to five MRS studies, a total of 72 MRS imaging studies were performed over 3.5 years. Repeated MRS studies were not based on a fixed time interval and the reasons for the repeated studies were not explicitly stated.

A 1.5 Tesla MR imager (manufacturer not stated) was used to acquire multi-voxel spectra. Nominal voxel size was 0.83 cm^3^. At the time of each MRS study, a combination of clinical examination, MRI, positron emission tomography with 18F-fluorodeoxyglucose, and biopsy findings (when available) were used to categorize each patient as having either stable or progressive disease.

The signal amplitude of each metabolite (Cho, NAA, Cr, Lac) in the tumor region of interest was normalized to the corresponding amplitude in a matching region of interest from a normal area of the contralateral brain in order to calibrate the signal intensities from different imaging studies and individuals to a common scale. The investigators used the percentage changes in the normalized Cho signal intensity between two consecutive studies to categorize patients into stable and progressive groups. They found that all progressive cases could be correctly classified using a Cho signal increase of more than 45% and all stable cases had increases of less than 35%. Thus, using a threshold of 40% Cho signal increase between visits, the sensitivity was 100% and specificity was 100%.

In addition to the normalized Cho measurements, the investigators also analyzed normalized NAA, Cr, and Lac, as well as the within-voxel metabolite ratios (NAA/Cho, NAA/Cr, Cho/Cr). Other than the normalized Cho measurement, they found no association of the other measurements with disease progression.

### 3.2.4 Differentiating Intracranial Cystic Lesions

Shukla-Dave et al. (2001) prospectively evaluated the accuracy of MRS in the differentiation of intracranial cystic lesions. Fifty-one patients including 23 men and 28 women between the ages of eight and 50 years (mean 33 years) with intracranial cystic lesions on conventional MRI were studied. Single-voxel MRS was performed using a 1.5 Tesla MR system (Magnetom, Siemens) on lesions greater than 8 cm^3^. A VOI of 4 to 8 cm^3^ within the confines (sometimes including the rim) of the lesion was selected for MRS.

The criteria used to establish the diagnosis of cystic lesions were:

- Abscesses: lipid/lactate at 1.3 and amino acids at 0.9 ppm in all with/without additional resonances of succinate, acetate, alanine and glycine
- Glioma: lipid and/or lactate with choline
- Arachnoid cyst: presence of small resonance of lactate with very low signal to noise spectrum
- Hydatid cyst: very large succinate peak with lactate, alanine, acetate with absence of amino acids

Two investigators who did not know the MRI results, except that the lesions were cystic, interpreted the MRS spectra independently. However, the rate of discrepancies and the method of resolution of discrepancies in the interpretation of the spectra results between the two investigators were not reported. The pre-operative diagnosis was based solely on the MRS results. All patients presumably underwent surgery for the intracranial cystic lesions. The final diagnosis was based on the results of histopathology, aspiration and culture of the contents. Fifty MRS spectra out of 51 were interpretable. Data for one case of acoustic neuroma was of poor quality and not included in the analysis.

Of the 51 cases, MRS correctly identified all 21 cases of abscess, all 19 cases of glioma, all three cases of arachnoid cyst, and all three cases of hydatid cyst. MRS incorrectly diagnosed one case of xanthogranuloma and one case of infarct as glioma. A total of three inconclusive MRS diagnoses were later found to be glioblastoma multiforme, glioependymal cyst, and acoustic neuroma. Thus, MRS correctly diagnosed the pathology of intracranial cystic lesions in 46 of 51 (90%) cases, did not contribute to the diagnosis in three cases (6%) and falsely diagnosed benign lesions as malignant in two cases (4%).

## 3.3 Category-3: Studies Conducted to Evaluate Diagnostic Thinking Impact

Two small prospective studies qualified for this category. The purpose of the study by Hall et al. (2001) was “to determine the utility of intraoperative MRS for targeting during brain biopsy using a skull-mounted trajectory guide.” The trajectory guide is commercially available and has been approved by the Food and Drug Administration (FDA) for the placement of deep brain stimulators, drug delivery catheters, and brain biopsies (Hall et al., 2001). The successful use of intraoperative MRS-guided brain biopsy might replace the conventional frame-based or frameless stereotactic techniques guided by either computed tomography (CT) or magnetic resonance imaging (MRI). In this setting, the CT or MRI are typically performed immediately or a few days before the biopsy. However, the opening of the dura mater and with the loss of cerebrospinal fluid may result in shifting the position of the lesion identified in the imaging studies (brain shift), which in turn might result in non-diagnostic stereotactic biopsy. A review of stereotactic brain biopsies found a diagnostic yield (proportion of biopsies containing useable diagnostic tissue) of 91% (Hall, 1999).

A total of 17 patients including 13 men and four women between the ages of 16 and 80 years suspected of brain tumors were evaluated in Hall’s 2001 prospective study. All patients had “turbo spectroscopic imaging (TSI)” (a multi-voxel MRS method) and seven patients had single-voxel spectroscopy in addition, for purposes of comparison. MRS spectra were obtained using 1.5 Tesla MR system (ACS-NT; Philips Medical Systems, Best, Netherlands) located within an intraoperative MRI suite. The VOI in the single voxel spectroscopy was 1.5×1.5×1.5 cm^3^ and the TSI used a 32×32 grid of spectra in a single plane with a spatial resolution of 0.66×0.66×2.0 cm^3^.

Turbo spectroscopic imaging was successfully obtained in all 17 patients. The investigators noted that the TSI spectra in one case of radiation necrosis did not correlate well with the single voxel spectra. The TSI spectra in general had lower spectroscopic resolution and often contained lipid signals that were not evident on single voxel spectra. Three lesions did not demonstrate regions of elevated choline on the TSI images, which were later histologically confirmed to be brain tumors.

All 17 biopsies guided by MRS yielded diagnostic tissues, which included six glioblastoma multiforme, three anaplastic astrocytoma, three anaplastic oligodendroglioma, two radiation necrosis, one germinoma, one ganglioglioma, and one astrocytoma. No radiographically or clinically significant hemorrhage associated with MRS guided brain biopsies using the trajectory guide was reported among the 17 patients.

The authors concluded that “intraoperative MRS-guided brain biopsy using a trajectory guide is a simple, safe, and accurate technique for accessing areas of the brain of diagnostic interest.” They further commented that with the development of intraoperative MRS, it is now possible to biopsy lesions located in the brain without the use of rigidly fixed head frames (traditional stereotaxy) and in near real-time, thus improving the accuracy and diagnostic yield. The use of the trajectory guide with MRS may also reduce intracerebral hemorrhage complications by minimizing the number of needed passages of the biopsy needle.

While the combination of trajectory guide and intraoperative MRS in this study appears promising in achieving high yield in brain biopsies, the number of patients studied was small. The need for an intraoperative MRI suite limits the generalizability. It should also be noted that three of the four authors of this study disclosed a financial interest in the company that produces the trajectory guide.

Lin et al. (1999) prospectively evaluated the utility of single voxel MRS when used as an alternative or adjunct to brain biopsy in patients with lesions suggestive of brain tumors initially identified by MRI. This study provided information for diagnostic thinking impact (Category- 3) as well as for therapeutic choice impact (Category- 4).

Fifteen patients between the ages of seven and 58 (there was only one child of age 7) were studied. Among the diagnoses based on histology were six anaplastic astrocytoma, one astrocytoma, one oligodendroglioma grade II, one oilgodendroglioma grade III, one glioblastoma multiforme, and one abscess. Three additional patients did not have biopsy and the lesions resolved on serial scans. One patient with a history of treated brain stem mass subsequently died from progressive disease on follow-up. A neurosurgeon defined a treatment plan that would be carried out in the absence of a diagnostic MRS study prior to the MRS examination, to determine whether MRS directly impacted upon and altered clinical decision-making. MRS interpretations were directly incorporated into the clinical decision-making and a treatment plan was determined. Patients were then followed to determine if subsequent treatment and outcomes were in accordance or discordance with the MRS findings.

Single-voxel MRS was performed on a 1.5 Tesla Signa Scanner (GE Medical Systems, Milwaukee, WI). The VOI was determined by the neurosurgeon based on MRI results prior to the MRS exam. The voxel size was adjusted to optimize the amount of homogeneous abnormal tissues within the voxel, while minimizing the amount of necrotic tissue. Voxel size varied between 2.35 to 9.68 cm^3^.

The MRS spectra were quantified with an external standard although it was not described. NAA/Cr ratios were consistently and significantly elevated in non-neoplastic spectra whereas Cho/Cr demonstrated the opposite trend. Lipid and lactate were only observed in abscesses and one-half of neoplastic spectra. They could not reliably differentiate necrotic tumor from radiation necrosis or abscess. Myoinositol/creatine ratios were not significantly different between groups.

Forty-one VOI from 15 patients were analyzed. Thirty-five (85%) of the spectra were considered to be of good or excellent quality,four (9%) of poor but interpretable quality, and two (4%) non-interpretable. For 10 patients with previously documented tumors, MRS was interpreted as consistent with recurrent tumors in seven cases and consistent with radiation necrosis in three cases.

In one patient with two regions of interest on MRI, MRS suggested tumor in one lesion, but interpreted another lesion as edematous white matter without tumor. Disease progression occurred in the edematous white matter lesion 9 months after initial surgery, indicating that MRS was unsuccessful in identifying infiltrating tumor in this instance. A retrospective review of the spectra in that region suggested that the effect of averaging over a large volume might have resulted in the misinterpretation. The authors suggested that a multi-voxel MRS might have been able to provide a more accurate diagnosis.

In the absence of MRS, the neurosurgeon would have recommended stereotactic biopsy in eight cases, serial MRI at six week intervals in three cases, repeat craniotomy in three cases, and empiric chemotherapy in one case. MRS was used in place of biopsy in seven cases, and correlated with clinical course in six of these cases. Overall, MRS was found to directly alter clinical management in 12 of 15 patients and provided greater support for clinical management in 14 of 15 patients. Had MRS been relied upon in every case, it might have avoided biopsy in nine cases, and influenced clinical management in 13 of 15 patients.

The small number of patients, narrow spectrum of diagnoses, and the inclusion of only one neurosurgeon’s decision limit the generalizability of this study.

## 3.4 Category-4: Studies Conducted to Evaluate Therapeutic Choice Impact

### Prospective studies

The prospective study by Lin et al. (1999) also provided limited information on the use of the test on therapeutic choice impact. See the discussion under Category-3 above.

### Retrospective study

Adamson et al., (1998) conducted a retrospective review of medical records to assess the influence of single-voxel MRS findings on the treatment of patients suspected of having a brain tumor. This publication appears to be based on the same overlapping patient population from the Medical College of Wisconsin that had been used in two other Category-2 publications.

The medical records of 90 patients who had MRS between May and December of 1995 were examined. Seventy-eight met the inclusion criteria and provided sufficient data for analysis. The patients were categorized into two groups based on the interpretation of the MRS findings:

- Group 1, MRS findings positive for neoplasm
- Group 2, MRS findings negative for neoplasm

The investigators examined all available medical records, including discharge summaries, progress notes, and outpatient reports to determine the outcome and treatment subsequent to the MRS examination. The patients were further categorized on the basis of whether they underwent biopsy before treatment. Pathology records in those patients who underwent surgical intervention or biopsy were reviewed.

MRS was classified as having a potential positive influence on treatment if no biopsy was needed before the initiation of treatment. If MRS results did not agree with the subsequent clinical diagnosis, the results were considered to have a potential negative influence on patient treatment. In all other cases, the effect of MRS was presumed to be negligible or indeterminate.

Neuroradiologists interpreted MRS spectra on the basis of the relative amplitudes for lactate, lipids, NAA, creatine and phosphocreatine, choline-containing compounds, and myo-inositol. A Cho/NAA ratio greater than 1.0 was considered to be positive for neoplasm. Smaller increases in the choline concentration were not considered diagnostic for neoplasm. The presence of lactic acid or lipid was consistent with relatively high-grade neoplasia if the choline concentration was elevated. Elevation of lactic acid without elevation of the choline concentration was considered more consistent with infarct than with tumor.

MRS was positive for neoplasm in 49 of the 78 patients. In eight of these 49 patients, MRS was classified as having a potential positive influence. These eight patients received radiation therapy, chemotherapy, or both, for a presumed neoplasm without a biopsy to confirm the presence of a tumor. MRS was negative for neoplasm in 29 of 78 patients. In 15 of these 29 patients, MRS was classified as having a potential positive influence.

MRS was classified as having a potential negative influence on patient treatment in two of the 49 patients diagnosed as having neoplasm by MRS. One of these two patients underwent biopsy, which showed inflammatory reaction as probably being secondary to demyelination. The other patient underwent surgery and was found to have arteriovenous malformation. MRS had no influence on patient treatment in 37 patients diagnosed with brain tumor by MRS.

Because of the nature of retrospective medical record review, there were several problems with this study. Fourteen of the 78 patients had incomplete follow-up information, two from the MRS- diagnosed “tumor” group and 12 from the MRS “non-tumor” group. The patients study were highly selected. The decision to perform MRS was based on CT and MRI results in which a neoplasm was considered to be the prime candidate in the differential diagnosis.

## 3.5 Category- 5: Studies Conducted to Evaluate the Impact of Test on Health Outcomes

No study was identified for this category.

## 3.6 Category 6: Studies Conducted to Evaluate the Use of Test on Societal impact

No study was identified for this category.

The following table summarizes our assessment of the Category-2 and above studies described above.

| Author | Objective | Sample N/gender/ mean age | Design | Assessment of accuracy or usefulness of MRS | Limitations
CATEGORY 2: TEST PERFORMANCE
• Differentiating neoplasm from non-neoplasm
| Rand et al. (1997) | Normal vs. non-normal; neoplasm vs. non-neoplasm | 31 ♂ 22♀ age=41 | Prospective series of patients. with suspected or recurrent neoplasm | Moderate | small sample size
| Butzen et al. (2000) | Neoplasm vs. non-neoplasm | 99 spectra 31 ♂ 22♀ age=41 | Logistic regression analysis | Moderate | Only study to use Cho/NAA ratio
| McKnight et al.(2002) | Neoplasm vs. non-neoplasm | 100 biopsies | Prospective Linear model | Moderate | Unclear enrollment, unblinded, limited generalize-ability
| Kimura et al. (2001) | Neoplasm vs. non-neoplasm | 29 ♂ 16♀ age 26–75 | Retrospective patients with lesions | Moderate | Selection bias, small sample, homogeneous lesions
• Clinical utility of MRS added to MRI
| Moller-Hartman et al. (2002) | Neoplasm vs. non-neoplasm | 176 | Consecutive series of patients with lesions | High | Did not report how reading discrepancies resolved
• Grading of tumors
| Roser et. al. (1997) | Grading glial tumors | 17 | Suspected glial tumors | Moderate | Small sample; homogeneity of lesion type
| Tedeschi et al. (1997) | Malignant degeneration and recurrence | 27 | Prospective 3 yr. follow-up of patients w/known tumors | High | Small sample
• Differentiate intracranial cystic lesions
| Shukla-Dave et al, (2001) | Differentiating Intracranial cystic lesions | 23 ♂ 28♀ age=33 | Prospective patients w/intracranial lesions dx. by MRI | High | Possible observer bias due to non reporting of method for resolving difference in interpreting spectra; sample size?

Category | Author | Objective | Sample | Design | Assessment of accuracy or usefulness of MRS | Limitations
CATEGORY 3: DIAGNOSTIC THINKING IMPACT
| Hall et al. (2001) | Utility of MRS for targeting biopsies | 13 ♂ 4♀ age 16–80 | Prospective patients w/suspected tumors | High | Small sample; need for intra-operative MRI suite
| Lin et al. (1999) (also Category-4) | Supporting brain biopsy for MRI-identified lesions | 15 Age 7–58 | Prospective | High | Small sample, homogeneous group of diagnoses, limited observer verification
CATEGORY 4. THERAPEUTIC CHOICE IMPACT
| Adamson et al. (1998) | Evaluation of impact of MRS on biopsy decision | 90 initial; 78 final | Retrospective patients w/suspected neoplasms dx. By CT or MRI See Rand et al.; same data. | Low | Retrospective, losses to follow-up; medical record reviews
| Lin et al. (1999) (also Category-3) | Supporting brain biopsy for MRI-identified lesions; some patients were treated based on MRI findings | 15 Age 7–58 | Prospective | High | Small sample, homogeneous group of diagnoses, limited observer verification