# METHODS

## 2.1 Classification of diagnostic studies

The Medicare Coverage Advisory Committee (MCAC) report on “Recommendations for Evaluating Effectiveness; Executive Committee Working Group Medicare Coverage Policy” (Executive Committee Working Group, 2001) (http://www.cms.hhs.gov/mcac/8b1-i9.asp) developed recommendations for evaluating evidence. It pointed out that although direct evidence is preferable, few studies directly measure the effect of diagnostic tests on health outcomes. Rather, studies typically focus on whether diagnostic tests are technically feasible or on effects on accuracy. These points apply to MRS. Few well-designed studies evaluate the impact of this test on clinical outcomes.

To systematically review the level of assessment of each study, we used a model described by Fineberg et al. (1977), Fryback and Thornbury (1991), and Adams (1997) to categorize the level of assessment achieved by the studies:

CATEGORIES OF DIAGNOSTIC ASSESSMENT

CATEGORY | CATEGORY DESCRIPTION | EXAMPLES OF MEASURES
1 | Technical feasibility and optimization | Ability to produce consistent spectra
2 | Diagnostic accuracy | Sensitivity and specificity
3 | Diagnostic thinking impact | % of times clinicians’ subjective assessment of diagnostic probabilities change
4 | Therapeutic choice impact | % of times therapy planned prior to MRS changed after MRS
5 | Patient outcome impact | % of patients who improved with MRS compared to % without MRS
6 | Societal impact | Cost-benefit analysis

Note that the Institute of Medicine has also described similar criteria for evaluating diagnostic tests.

According to the MCAC assessment criteria, the studies most useful for assessing MRS would be Category- 2 or higher. In consultation with AHRQ and CMS, it was decided to review in depth only Category- 2 and higher studies.

## 2.2 Literature search

An OVID search of the MEDLINE^®^ database was conducted on November 6, 2002. Filters and limitations were used to eliminate inappropriate publications, with inclusion and exclusion criteria developed to identify articles to be reviewed. The search used applicable MeSH headings and textwords with appropriate Boolean operators. After filtering irrelevant publication types, the search resulted in 959 citations for download and screening. Hand screening of the abstracts resulted in accepting 137 citations for complete article retrieval. All abstracts were reviewed to identify full articles that met the criteria.

In addition, abstracts from the following relevant professional society proceedings for the years 2001 and 2002 were reviewed and included in the analyses:

- American Society of Neuroradiology (ASNR)
- Radiological Society of North America (RSNA)
- International Society for Magnetic Resonance in Medicine (ISMRM)

Note that the information available from abstracts in such proceedings is extremely limited in comparison to that available in full articles. Additionally, the peer review process is generally not comparable to the process for full articles. Finally, the International Network of Agencies for Health Technology Assessment (INAHTA) (http://www.inahta.org/) and National Guidelines Clearinghouse (NGC) (http://www.guideline.gov/index.asp) databases were searched for relevant citations.

## 2.3 Inclusion/Exclusion Criteria

The inclusion criteria for accepting studies included the use of hydrogen proton magnetic resonance spectroscopy (hydrogen) MRS on patients with suspected or known brain tumors. Only in vivo studies with a minimum of six adult human subjects were included. Explicitly excluded were studies of only healthy patients or studies of exclusively HIV/AIDS patients. In addition, studies of phosphorus or other types of MRS were excluded.

## 2.4 Search Results

One hundred thirty-seven publications were retrieved. Further review of those retrieved publications with application of inclusion criteria yielded 85 studies for inclusion in the report. The detailed search strategy follows:

MEDLINE <1966 to October Week 4 2002>
# | Search History | Results
1 | exp Magnetic Resonance Spectroscopy/ | 92891
2 | limit 1 to human | 22632
3 | limit 2 to English language | 20499
4 | exp neoplasms/ | 1409117
5 | (tumor or cancer$ or neoplasm$ or neoplas$ or lesion$ or mass).tw. | 1131920
6 | (brain or cranial or cerebr$).tw. | 479504
7 | 5 and 6 | 71583
8 | 4 and 6 | 50293
9 | 7 or 8 | 93338
10 | exp brain neoplasms/ | 69674
11 | 3 and (9 or 10) | 1231
12 | limit 11 to (addresses or bibliography or biography or
# | Search History | Results
| dictionary or directory or editorial or festschrift or historical article or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index) | 24
13 | Case Report/ | 1059907
14 | 11 not (12 or 13) | 959

Two hundred forty-one abstracts were identified in the search of the three professional society proceedings and fifty-one met the inclusion criteria and are included in this report. No relevant material was identified in either the INAHTA or NGC databases.

## 2.5 Data Extraction

As described above, our review entailed classifying each study into five categories. For those studies in Category- 1 we extracted data summarizing the following aspects of each study for later use in an evidence table: study characteristics (design, enrollment, patient characteristics), MRS technical aspects (number and volume of voxels), and study objectives (differential diagnosis and treatment planning).

For the studies in Category- 2 and above, narrative analyses were provided for each study. Studies in these categories were also evaluated with respect to their methodological adequacy.