# INTRODUCTION

## 1.1 Background

Diagnosing and treating space-occupying tumors of the brain presents special challenges due to the similarities of tumors to other pathologic entities on conventional imaging, the similarities of individual tumor cell types on conventional imaging, the inaccessibility of these lesions and their proximity to complex brain structures. Standard imaging diagnostic procedures include computerized tomography (CT), magnetic resonance imaging (MRI), single photon emission computed tomography (SPECT), and positron emission tomography (PET) imaging. Following is a summary of invasive and non-invasive means of diagnosing brain tumors:

Tech- nique | Degree of Invasiveness | Description
Biopsy | Invasive | Extraction of tissue for histopathological diagnosis. The reference standard.
CT | Noninvasive Uses ionizing radiation | Computed 2-dimensional map of the attenuation voxels of tissue using externally generated x-rays delivered in a circular fashion.
MRI | Noninvasive No ionizing radiation | Spatial localization of tissue properties that relate to alignment of protons in strong magnetic fields.
SPECT | Noninvasive Uses radio-isotopes | Spatially localizes emitted photons (gamma rays) after administration of radioactive agent.
PET | Noninvasive Uses radio-isotopes | Spatially localizes emitted positrons after administration of radioactive agent.
MRS | Noninvasive No ionizing radiation | Spatial localization of tissue chemical properties that relate to alignment of protons in strong magnetic fields. Proton (hydrogen) MRS uses the frequency response of hydrogen, while other versions examine the frequency response of other elements (phosphorus and sodium).

Confirming the preliminary diagnosis requires tissue biopsy to assess the histologic composition of the brain tissue in question. A non-invasive technique that could provide information about the chemical and histologic composition of brain tissue could greatly aid diagnosis and treatment of brain tumors by helping to avoid unnecessary biopsies, by helping to guide biopsies, and by providing additional information for improving treatment.

Magnetic Resonance Spectroscopy is a technique related to magnetic resonance imaging (MRI). Both techniques rely on the tendencies of some proportion of protons to align with or against a strong magnetic field. MRI refers to localizing the total tissue signal produced by a small, localized collection of tissue (voxel). The tissue signal is produced by the rates of magnetic alignment (or decay) of the protons in two planes as well as the overall proton density. T1 relaxation refers to alignment with the magnetic field, and T2 relaxation refers to alignment perpendicular to the magnetic field). This phenomenon is produced by stimulating the blocks of tissue with a broad-spectrum signal that disrupts the magnetic alignment. The signal is eventually produced, after electromagnetic manipulation, as the protons re-align themselves to their original configurations.

MRS, on the other hand, relies on a very different phenomenon of proton alignment with the magnet that is based on frequency. The ability of the alignment of protons to be disrupted is frequency dependent. The exact frequency that disrupts the alignment depends on the chemical structures containing the protons. In MRS, tissue blocks (or voxels) are stimulated with very narrow bandwidth frequencies, and a graph is made of the signal strength vs. the frequency of stimulation. This produces characteristic peaks related to the amount of certain chemical compounds present in the tissue. MRS, therefore, has the potential to provide information about specific metabolites in brain tissue that can indicate the presence of tumor, necrotic tissue, and other pathologic entities. It should be noted that MRS has been evaluated as a diagnostic tool for a variety of diagnostic applications including not only CNS tumors but other non-CNS conditions. In this report, we exclusively examine MRS for brain tumors.

Finally, the majority of brain tumor studies focus on proton (hydrogen) MRS, but other elements (i.e. phosphorus and sodium) are used. This report deals with proton hydrogen MRS (to be referred herein simply as “MRS”).

## 1.2 Requests by the Centers for Medicare and Medicaid Services

The Centers for Medicare & Medicaid Services (CMS) requested a technology assessment by the Agency for Healthcare Research and Quality (AHRQ) to assess the value of MRS for diagnostic evaluation, surgical planning, and patient management of space-occupying brain tumors. Also requested was a review of factors that may affect the performance of MRS. The Tufts-New England Medical Center Evidence-based Practice Center was asked to conduct an assessment of this technology. For patients presenting with signs or symptoms of a space-occupying brain lesion, the key questions to be addressed were:

1. For what metabolic profiles does the yield of MRS provide equivalent, complementary, or more accurate diagnostic information for (i) initial diagnosis, (ii) recurrence, or (iii) assessing therapy than
  - Brain biopsy
  - Conventional anatomic imaging studies
  - MRS + conventional anatomic imaging studies vs. brain biopsy
2. Does the use of MRS lead to an improved net health outcome by
  - Avoiding unnecessary biopsy
  - Obtaining appropriate biopsy, from appropriate location
  - Directing biopsy to an appropriate location
  - Receiving appropriate treatment
  - Avoiding an inappropriate treatment
3. Are voxel positions and operator error important factors in obtaining diagnostic images? If so, how do they impact MRS accuracy?

## 1.3 Analytic Framework

To address these issues we developed an analytic framework describing each of the potential uses of MRS. Potential uses of MRS are described for patients newly diagnosed with a space-occupying brain mass as well as for patients with a previously diagnosed brain tumor undergoing treatment. The potential uses include diagnostic evaluation and prognostication, patient management and planning for surgery, and potential outcome measures for evaluating performance. Factors that might affect performance are also included in the framework, which is presented in Appendix A.

### 1.3.1 Diagnostic evaluation

Experimentation with in-situ Magnetic Resonance Spectroscopy (MRS) for tumor assessment has been ongoing since 1985 (Maris et al., 1985). It was initially hoped that MRS would provide definitive spectrographic signatures of tumor histologic types. Clinical MRS research has led to multiple specific applications of MRS for both diagnostic work- ups and treatment follow-up of CNS tumor. Combined with findings from conventional anatomic MRI, MRS may have the potential to improve the diagnosis and management of brain tumors.

Primary diagnostic categories where some authors have suggested that MRS may present important diagnostic information are:

#### Distinguishing single metastatic lesions from primary tumors of the CNS, such as astrocytomas

This distinction is important, because single brain metastatic lesions would trigger a whole-body diagnostic workup for the source of the tumor, whereas primary brain tumors would be staged and treated as such. The treatment regimens for different metastatic types of tumors vary greatly. In virtually all cases, metastatic lesions are treated with regimens considerably different than primary brain tumors, so establishing the exact nature of the neoplasm is exceedingly important in treatment planning.

#### In distinguishing abscesses from CNS tumors

Diagnosing an abscess quickly is critical. The clinical presentation of tumors and CNS abscesses in the Medicare population overlap significantly. Mistaking an abscess for a tumor can lead to a significant delay in diagnosis that can be catastrophic, because diagnosing a tumor may involve a relatively long workup. Rapid intervention in the case of an abscess can result in minimizing neurologic damage, leaving the patient in a high-functioning state.

#### Tumor grade

In primary CNS tumors, MRS may provide a more accurate means of determining tumor grade, and hence prognosis, than conventional anatomic MRI imaging with the contrast agent, gadolinium. Currently, tumor grade is estimated by its potential to enhance with gadolinium. The specificity of this diagnostic means is only moderate. Establishing the grade is important in determining treatment protocol. Low-grade tumors are often simply watched, whereas high-grade tumors are often de-bulked, irradiated and sometimes treated with chemotherapy. If a technique produces sufficient specificity for tumor grade, a biopsy could be foregone in many instances. MRS may have an advantage over biopsy in reducing sampling error as well.

#### In distinguishing peripheral neuroectodermal tumors (PNET) from astrocytic lesions in adults

The ability to distinguish these tumors reliably could speed treatment of PNETs. These are typically very aggressive tumors that may sometimes respond to chemotherapy more readily than astrocytic tumors. Similarly, it is important to distinguish “bright spots” on conventional T2-weighted MRI imaging, associated with neurofibromatosis type 1 (NF1), from astroglial tumors occurring in this same patient population. Neurofibroma bright spots are hamartomas that typically do not expand in size. Follow-up exams are usually not necessary. The astrocytomas associated with NF1 are low grade, and typically do not progress to high-grade tumors. Nonetheless, they can grow in size and are typically followed with imaging studies.

#### Biopsies

MRS has also been recently investigated for use in biopsies. Biopsy guidance is an area where MRS may reduce sampling error associated with determination of tumor grade (and prognosis) in primary CNS tumors. Accurate determination of tumor grade is important in determining prognosis and adjuvant therapy.

### 1.3.3 Patient management and planning for surgery

The management of CNS tumors depends on tumor type and multiplicity. In primary astrocytomas of the CNS, treatment depends on grade. Low-grade tumors (WHO classification grades 1–2) are usually observed, with follow-up, if small, and do not represent an immediate neurological crisis. In cases of neurologic crisis, tumors are either excised or debulked. In high-grade astrocytomas, tumors are debulked surgically, followed by whole-brain radiation.

Single metastatic brain lesions have conventionally been excised when in accessible locations. Excision is often accompanied by chemotherapy. Multiple lesions have conventionally been treated with whole brain radiation and chemotherapy. Gamma knife therapy (focused stereotactical radiation) has become an important and increasingly used alternative means of treating both single and multiple metastatic lesions. Its use in single lesions depends on the primary tumor’s sensitivity to radiation.

In patients treated for CNS tumors, MRS may provide important diagnostic criteria for:

#### Determining tumor recurrence

Tumor recurrence changes the prognosis of patients. Because recurring brain tumors are associated with a shortened life span, prognosis is important for patients to plan the final stages of their lives. Prognosis can, in some cases, be improved by additional focused radiation. This treatment, either alone or with additional chemotherapy, is usually not administered until there is definite evidence of tumor recurrence.

#### Distinguishing radiation necrosis from tumor recurrence

The rate of tumor recurrence has prognostic value, as well as therapeutic implications. However, the presence of mixed recurrent tumor and radiation necrosis is common. Radiation necrosis would contraindicate additional radiation. While the effects are significant, they are not usually related to eventual mortality. Investigators have suggested that MRS could distinguish recurrent tumor from radiation necrosis under some circumstances.

#### Determining tumor response to therapy

Establishing that tumors are responding to the designated treatment is imperative, in determining if treatment (with its associated morbidity) should be continued, discontinued or changed to a different regimen.

#### Surgical treatment planning

Claims have been made that MRS provides important information for guidance of gamma knife therapy. It has been suggested that MRS has improved accuracy in determining tumor extent and better delineates the area to be treated with focused radiation.

### 1.3.4 Factors that may affect performance of MRS

#### Location of lesion including proximity to bone and sinuses

The technique of MRS requires careful “shimming” of the magnetic fields --- adjusting the magnetic fields around the tissue of interest so that these fields are homogeneous. Variations in the magnetic fields mis-register the spectral peaks, as the frequency sensitivities of chemical structures are also affected by the external magnetic field strength. Sudden dramatic changes in tissue composition, such as adjacent air or bone, can result in the inability to correctly shim the magnet field. This can result in distorted and non-usable data. Therefore, lesions that are small, and abut bone or air-filled structures, such as the sinuses, can present problems during MRS analysis.

#### Operator issues

While standard MRI technologists are seldom specifically trained in MRS, commercial software has become available that is less sensitive to operator error. Nevertheless, many current uses of MRS for brain tumors require precise localization that demands an understanding of MRS positioning requirements that with which many technologists are not acquainted. Multivoxel MRS techniques may have reduced these problems to some degree. However, accurate placement to achieve the desired results is still necessary. It may therefore be necessary for a trained neuroradiologist familiar with MRS to be available for voxel placement.

#### Size/position of voxel

Current commercial software enables either multivoxel or single voxel spectroscopy to be performed. Manufacturers have pre-set values for slab thickness and voxel size in their software. However, if mandated by conditions, these parameters may be changed by the investigator. Likewise, in single voxel studies, there are default values for voxel size and position. However, specific conditions, such as tumor size, location and relative positioning of the voxels near artifact-producing structures can require changes in size. The investigator must remember that the time of acquisition changes with the cube of the volume or square of the area. Additionally, the voxels must avoid overlapping with structures containing only cerebrospinal fluid, such as the ventricles, Sylvian fissure and choroidal fissures. These regions contain some, but not all, of the chemical compounds analyzed in the brain. Hence they can distort key ratios in the compounds used in interpretation.

#### Concurrent disease

Concurrent disease can occasionally produce problems when using MRS for evaluating tumors. Tumors lying near areas of old infarcts and ischemic changes can distort chemical ratios used in interpretation. Similarly, concurrent demyelinating disease can produce additional distortions. In general, with single voxel technique, careful voxel placement, and containing voxels from appropriate control areas can alleviate the problem. Alternatively, selecting appropriate voxels from control areas in a multivoxel study could accomplish the same objective.

#### Hardware and software

Hardware and software both affect the application of MRS. In general, studies on magnets with field strengths less than 1.5 tesla (unit of magnetic flux) require too much time to be used on a routine basis. High field strength magnets, such as current 3 tesla systems have a time advantage (that can be converted into a space localization advantage).