# GLOSSARY

Cho: choline
cm^3^: cubic centimeter
Cr: creatine and phosphocreatine
CT: computed tomography
GI: glycine
Lac: lactate
Lip: lipid
MGG: macromolecules, glutamine, and glutamate
MI: myo-inositol
MR: magnetic resonance
MRI: magnetic resonance imaging
MRS: magnetic resonance spectroscopy
NAA: N-acetyl-aspartate
ODV: orthonormal discriminant vector
PET: positron emission tomography
PNET: peripheral neuroectodermal tumor
ROC: receiver operating characteristic
VOI: volume of interest
Tesla: unit of magnetic flux