# ANALYTIC FRAMEWORK: POTENTIAL USES OF MRS

Newly Diagnosed Space-Occupying Brain Mass* Identified By CT or MRI | Follow-Up Of Patients with Previously Diagnosed Brain Tumor Undergoing Treatment
Potential use of MRS in diagnostic evaluation and prognostication
- Replacement of diagnostic biopsy by MRS; - Outcome measure: same or improved accuracy/less invasiveness; - Differentiating masses; - Distinguishing malignant neoplasms from non-malignant neoplasms and vascular lesions (e.g. ring-enhancing primary tumors from abscesses); - Distinguishing single metatstatic lesions such as gliomas from primary tumors; - Distinguishing among types of neoplasm (e.g. PNET from astrocytoma or neurofibroma bright spots from astroglial tumors); - Outcome measure: Higher sensitivity and specificity in differentiating masses; - MRS-guided biopsy to improve biopsy yield; - Outcome measure: Success rate of MRS-guided biopsies; - Tumor grading: degree of malignancy; - Outcome measure: % of inappropriate biopsies avoided; biopsy yield | - Determining whether tumor has recurred; - Differentiate recurrence from radiation injury (necrosis); - Outcome measure: Higher sensitivity and specificity in differentiating masses; - MRS-guided biopsy to improve biopsy yield; - Outcome measure: Success rate of MRS-guided biopsies
Potential use of MRS in patient management
- Planning treatment; - Choosing among therapies; - Identifying tumor margin and volume for radiosurgery planning/surgical resection; - Identifying tumor margin and volume for radiotherapy (gamma knife therapy) planning; - Identifying target volume (isolating most active portions of tumor) for radiosurgery planning; - Tumor grading: timing interventions; - Outcome measures: survival, quality of life | - Re-initiating radiosurgery when recurrence differentiated from necrosis; - Rapidly assessing treatment effectiveness to optimize treatment; - Monitor response to treatment; - Outcome measures: survival, quality of life
Factors potentially affecting MRS performance
- Lesion location (e.g. proximity to bone and sinuses) and voxel positions; - Concurrent disease (suspicion of known Ca elsewhere, e.g. lung, breast); suspicion of HIV; - Operator error; - Machine used/software and equation version | - Lesion location (e.g. proximity to bone and sinuses) and voxel positions; - Concurrent disease (suspicion of known Ca elsewhere, e.g. lung, breast); suspicion of HIV; - Operator error; - Machine used/software and equation version