# References and Bibliography

ACC/AHA Guidelines for the evaluation and management of chronic heart failure in the adult. http://www.acc.org/clinical/guidelines/failure/hf_index.htm.
Aisiku I, Ander D, Knoepp L, Todd K. Noninvasive hemodynamic monitoring does not correlate with symptomatic improvement in the emergency department management of acute heart failure. Acad Emerg Med. 2000;7:465.
Antonicelli R, Savonitto S, Gambini C, et al. Impedance cardiography for repeated determination of stroke volume in elderly hypertensives: correlation with pulsed Doppler echocardiography. Angiology. Aug. 1991;42(8):648-653. [pmid: 1892240].
Arora RR, Carlucci ML, Malone AM, et al. Acute and chronic hemodynamic effects of enhanced external counterpulsation in patients with angina pectoris. J Investig Med. Nov. 2001;49(6):500-504.
Atallah MM, Demain AD. Cardiac output measurement: lack of agreement between thermodilution and thoracic electric bioimpedance in two clinical settings. J Clin Anesthesia. May. 1995;7(3):182-185.
Balestra B, Malacrida R, Leonardi L, et al. Esophageal electrodes allow precise assessment of cardiac output by bioimpedance. Crit Care Med. Jan. 1992;20(1):62-67. [pmid: 1729048].
Barin E, Haryadi DG, Schookin SI, et al. Evaluation of a thoracic bioimpedance cardiac output monitor during cardiac catheterization. Crit Care Med. Mar. 2000;28(3):698-702. [pmid: 10752817].
Barone JE, Tucker JB, Rassias D, Corvo PR. Routine perioperative pulmonary artery catheterization has no effect on rate of complications in vascular surgery: a meta-analysis. Amer Surg. 2001;67(7):674-679. [pmid: 11450787].
Barry BN, Mallick A, Bodenham AR, et al. Lack of agreement between bioimpedance and continuous thermodilution measurement of cardiac output in intensive care unit patients. Crit Care. 1997;1(2):71-74. [pmid: 11056698].
Belardinelli R, Ciampani N, Costantini C, et al. Comparison of impedance cardiography with thermodilution and direct Fick methods for noninvasive measurement of stroke volume and cardiac output during incremental exercise in patients with ischemic cardiomyopathy. Am J Cardiol. 1996;15;77(15):1293-1301.
Belott P. Bioimpedance in the pacemaker clinic. AACN Clin Issues. 1999;10(3):414-418. [pmid: 10745711].
Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. 1986;1(8476):307-310. [pmid: 2868172].
Bogaard HJ, Hamersma WB, Horsch JL, et al. Non-invasive assessment of cardiac output during exercise in chronic obstructive pulmonary disease: comparison of the CO2-rebreathing method and electrical impedance cardiography. Physiological Measurement. Nov. 1997;18(4):327-338. [pmid: 9413866].
Bowling LS, Sageman WS, O’Connor SM, et al. Lack of agreement between measurement of ejection fraction by impedance cardiography versus radionuclide ventriculography. Crit Care Med. 1993;21(10):1523-1527. [pmid: 8403962].
Castor G, Klocke RK, Stoll M, et al. Simultaneous measurement of cardiac output by thermodilution, thoracic electrical bioimpedance and Doppler ultrasound. Br J Anaesth. Jan. 1994;72(1):133-138. [pmid: 8110539].
Charach G, Rabinovich P, Grosskopf I, et al. Transthoracic monitoring of the impedance of the right lung in patients with cardiogenic pulmonary edema. Crit Care Med. Jun. 2001;29(6):1137-1144. [pmid: 11395588].
Clancy TV, Norman K, Reynolds R, et al. Cardiac output measurement in critical care patients: Thoracic Electrical Bioimpedance versus thermodilution. J Trauma. Aug. 1991;31(8):1116-1120. [pmid: 1875438].
Connors AF, Speroff T, Dawson NV, et al. The effectiveness of right heart catheterization in the initial care of critically ill patients. JAMA. 2000;276(11):889-897. [pmid: 8782638].
Conway F, Critchley LA, Stuart JC, et al. A comparison of the haemodynamic effects of intrathecal meperidine, meperidine-bupivacaine mixture and hyperbaric bupivacaine. Canadian Journal of Anaesthesia. Jan. 1996;43(1):23-29. [pmid: 8665630].
Critchley LA. Impedance cardiography. The impact of new technology. Anaesthesia. 1998;53(7):677-684. [pmid: 9771176].
Critchley LA, Calcroft RM, Tan PY, et al. The effect of lung injury and excessive lung fluid, on impedance cardiac output measurements, in the critically ill. Intensive Care Medicine. Jun. 2000;26(6):679-685. [pmid: 10945383].
Critchley LA, Critchley JA. A meta-analysis of studies using bias and precision statistics to compare cardiac output measurement techniques. J of Clin Monitoring. 1999;15:85-91.
Critchley LA, Leung DH, Short TG. Abdominal surgery alters the calibration of bioimpedance cardiac output measurement. Int J Clin Monit Comput. Feb. 1996;13(1):1-8. [pmid: 8738594].
Critchley LA, Short TG, Gin T. Hypotension during subarachnoid anaesthesia: haemodynamic analysis of three treatments. Br J Anaesth. Feb. 1994;72(2):151-155. [pmid: 8110564].
De Maria AN, Raisinghani A. Comparative overview of cardiac output measurement methods: has impedance cardiography come of age?. Congest Heart Fail. Mar. 2000;6(2):60-73. [pmid: 12029189].
Demeter RJ, Parr KL, Toth PD, et al. Use of noninvasive bioelectric impedance to predict cardiac output in open heart recovery. Biol Psychol. Aug. 1993;36(1–2):23-32. [pmid: 8218620].
Doering L, Lum E, Dracup K, et al. Predictors of between-method differences in cardiac output measurement using thoracic electrical bioimpedance and thermodilution. Crit Care Med. Oct. 1995;23(10):1667-1673. [pmid: 7587231].
Drazner MH, Thompson B, Rosenberg PB, et al. Comparison of impedance cardiography with invasive hemodynamic measurements in patients with heart failure secondary to ischemic or nonischemic cardiomyopathy. Am J Cardiol. Apr. 15. 2002;89(8):993-995. [pmid: 11950446].
Executive Committee Working Group. Recommendations for Evaluating Effectiveness. http://www cms hhs gov/coverage/8b1-i9.asp (http://www.cms.hhs.gov/coverage/8b1-i9.asp). 2001. Feb. 23.
Felker CM, O’Connor CM. Inotropic therapy for heart failure: an evidence-based approach. Am Heart J. 2001;142:393-401. [pmid: 11526351].
Fineberg HV, Bauman R, Sosman M. Computerized cranial tomography. Effect on diagnostic and therapeutic plans. JAMA. 1977;238(3):224-227. [pmid: 406427].
Fuller HD. The validity of cardiac output measurement by thoracic impedance: a meta-analysis. Clin Invest Med. Apr. 1992;15(2):103-112. [pmid: 1534291].
Genoni M, Pelosi P, Romand JA, et al. Determination of cardiac output during mechanical ventilation by electrical bioimpedance or thermodilution in patients with acute lung injury: effects of positive end-expiratory pressure. Crit Care Med. Aug. 1998;26(8):1441-1445. [pmid: 9710107].
Greenberg BH, Hermann DD, Pranulis MF, et al. Reproducibility of impedance cardiography hemodynamic measures in clinically stable heart failure patients. Congest Heart Fail. Mar. 2000;6(2):74-80. [pmid: 12029190].
Haennel RG, Logan T, Dunne C, et al. Effects of sensor selection on exercise stroke volume in pacemaker dependent patients. Pacing & Clinical Electrophysiology. Sep. 1998;21(9):1700-1708. [pmid: 9744431].
Hall JB. Use of the pulmonary artery catheter in critically ill patients: was invention the mother of necessity?. JAMA. 2000;283(19):2577-2578. [pmid: 10815124].
Han JH, Lindsell CJ, Tsurov A, Storrow AB. The clinical utility of impedance cardiography in diagnosing congestive heart failure in dyspneic emergency department patients. Acad Emerg Med. 2002;9:439a-440a.
Handelsman H. Measuring Cardiac Output by Electrical Bioimpedance. Health Technology Assessment Reports. Rockville, MD. Agency for Health Care Policy and Research. 1992.
Hirschl MM, Kittler H, Woisetschlager C, et al. Simultaneous comparison of thoracic bioimpedance and arterial pulse waveform-derived cardiac output with thermodilution measurement. Crit Care Med. Jun. 2000;28(6):1798-1802. [pmid: 10890622].
Horstmann E, Konn B. Assessment of cardiac output during exercise. Transthoracic impedance vs. heart rate alone. Med Prog Technol. 1993;19(4):173-178. [pmid: 8052172].
Ivanov R, Allen J, Calvin J. The incidence of major morbidity in critically ill patients managed with pulmonary artery catheters: a meta-analysis. Crit Care Med. 2000;28(3):615-619. [pmid: 10752803].
Jewkes C, Sear JW, Verhoeff F, et al. Non-invasive measurement of cardiac output by thoracic electrical bioimpedance: a study of reproducibility and comparison with thermodilution. Br J Anaesth. Dec. 1991;67(6):788-794. [pmid: 1768552].
Jonsson F, Madsen P, Jorgensen LG, et al. Thoracic electrical impedance and fluid balance during aortic surgery. Acta Anaesthesiol Scand. May. 1995;39(4):513-517. [pmid: 7676789].
Kasznicki J, Drzewoski J. The importance of impedance cardiography in monitoring cardiac function in patients with hematological malignancies. Acta Haematol Pol. 1993;2:123-130. [pmid: 8372611].
Kazanegra R, Barcarse EA, Chen AJ, Maisel AS. Plasma levels of B-type natriuretic peptide (BNP) and non-invasive cardiac index in diagnosing congestive heart failure in the emergency department. 8^th^ Scientific Meeting of the Heart Failure Society of America abstracts. J Cardiac Failure. Aug. 2002;8(4). Suppl.
Kerkkamp HJ, Heethaar RM. A comparison of bioimpedance and echocardiography in measuring systolic heart function in cardiac patients. Ann N Y Acad Sci. Apr. 20. 1999;873:149-154. [pmid: 10372163].
Kindermann M, Frohlig G, Doerr T, et al. Optimizing the AV delay in DDD pacemaker patients with high degree AV block: mitral valve Doppler versus impedance cardiography. Pacing Clin Electrophysiol. Oct. 1997;20(10 Pt 1):2453-2462. [pmid: 9358487].
Kizakevich PN, Teague SM, Nissman DB, et al. Comparative measures of systolic ejection during treadmill exercise by impedance cardiography and Doppler echocardiography. Biol Psychol. Aug. 1993;36(1–2):51-61. [pmid: 8218624].
Lasater M. Impedance Cardiography: A Method of Noninvasive Cardiac Output Monitoring. American Assn. Of Crit. Care Nurses, Continuing Education. 2000. May. http://www.aacn.org/aacn/conteduc.nsf/e9737804d2e8882988256635006397cc/87b4e6ef367a23e0882569e00082d5ac?OpenDocument.
Lasater M. The view within: the emerging technology of thoracic electrical impedance. Crit Care Nurs Q. 1998;21(3):97-101. [pmid: 10646425].
Marrocco A, Eskin B, Nashed AH, et al. Noninvasive bioimpedance monitoring differentiates cardiogenic from pulmonary causes of acute dyspnea in the emergency department. SAEM annual meeting abstracts. Acad Emerg Med. 1998;5(5):476-477.
Mattar JA, Shoemaker WC, Diament D, et al. Systolic and diastolic time intervals in the critically ill patient. Crit Care Med. Nov. 1991;19(11):1382-1386. [pmid: 1935158].
Mehlsen J, Bonde J, Stadeager C, et al. Reliability of impedance cardiography in measuring central haemodynamics. Clin Physiol. Nov. 1991;11(6):579-588. [pmid: 1769191].
Milzman DP, Napoli A, Gerace T, et al. Acute treatment of heart failure with impedance cardiography monitoring of cardiac index and the ability to improve patient outcome. Society of Critical Care Management abstracts. Crit Care Med. 1999;27(12):A47.
Ng HW, Coleman N, Walley TJ, et al. Reproducibility and comparison of cardiac output measurement by transthoracic bioimpedance and thermodilution methods in critically ill patients. Clin Intensive Care. 1993;4(5):217-221. [pmid: 10146700].
Ovsyshcher I, Zimlichman R, Katz A, et al. Measurements of cardiac output by impedance cardiography in pacemaker patients at rest: effects of various atrioventricular delays. Journal of the American College of Cardiology. Mar. 1. 1993a;21(3):761-767. [pmid: 8436759].
Ovsyshcher I, Gross JN, Blumberg S, et al. Variability of cardiac output as determined by impedance cardiography in pacemaker patients. Am J Cardiol. Jul. 15. 1993b;72(2):183-187. [pmid: 8328381].
Ovsyshcher I, Gross JN, Blumberg S, et al. Precision of impedance cardiography measurements of cardiac output in pacemaker patients. Pacing Clin Electrophysiol. Nov. 1992;15(11 Pt 2):1923-1926. [pmid: 1279573].
Perko MJ, Jarnvig IL, Hojgaard-Rasmussen N, et al. Electric impedance for evaluation of body fluid balance in cardiac surgical patients. Journal of Cardiothoracic & Vascular Anesthesia. Feb. 2001;15(1):44-48. [pmid: 11254839].
Permanetter B, Rossy W, Klein G, et al. Ubiquinone (coenzyme Q10) in the long-term treatment of idiopathic dilated cardiomyopathy. Eur Heart J. Nov. 1992;13(11):1528-1533. [pmid: 1464342].
Perrino AC Jr, Lippman A, Ariyan C, et al. Intraoperative cardiac output monitoring: comparison of impedance cardiography and thermodilution. Journal of Cardiothoracic & Vascular Anesthesia. Feb. 1994;8(1):24-29. [pmid: 8167281].
Pickett BR, Buell JC. Validity of cardiac output measurement by computer-averaged impedance cardiography, and comparison with simultaneous thermodilution determinations. Am J Cardiol. May. 15. 1992;69(16):1354-1358. [pmid: 1585872].
Polanczyk CA, Rohde LE, Goldman L, et al. Right heart catheterization and cardiac complications in patients undergoing noncardiac surgery: an observational study. JAMA. 2001;286(3):309-314. [pmid: 11466096].
Porter JM, Swain ID. Measurement of cardiac output by electrical impedance plethysmography. J. Biomed Eng. 1987;9:222-231. [pmid: 3613546].
Raaijmakers E, Faes TJ, Scholten RJ, et al. A meta-analysis of three decades of validating thoracic impedance cardiography. Crit Care Med. Jun. 1999;27(6):1203-1213. [pmid: 10397230].
Raaijmakers E, Faes TJ, Kunst PW, et al. The influence of extravascular lung water on cardiac output measurements using thoracic impedance cardiography. Physiological Measurement. Nov. 1998a;19(4):491-499. [pmid: 9863675].
Raaijmakers E, Faes TJ, Meijer JM, et al. Estimation of non-cardiogenic pulmonary oedema using dual-frequency electrical impedance. Med Biol Eng Comput. Jul. 1998b;36(4):461-466. [pmid: 10198529].
Ritter P, Dib JC, Lelievre T, et al. Quick determination of the optimal AV delay at rest in patients paced in DDD mode for complete AV block. Eur J CPE. 1994;4(2):A163.
Sageman WS, Riffenburgh RH, Spiess BD. Equivalence of bioimpedance and thermodilution in measuring cardiac index after cardiac surgery. J Cardiothorac Vasc Anesth. Feb. 2002;16(1):8-14. [pmid: 11854871].
Sageman WS, Amundson DE. Thoracic electrical bioimpedance measurement of cardiac output in postaortocoronary bypass patients. Crit Care Med. Aug. 1993;21(8):1139-1142. [pmid: 8339577].
Scherhag AW, Stastny J, Pfleger S, et al. Evaluation of systolic performance by automated impedance cardiography. Ann N Y Acad Sci. Apr. 20. 1999;873:167-173. [pmid: 10372165].
Scherhag AW, Pfleger S, de Mey C, et al. Continuous measurement of hemodynamic alterations during pharmacologic cardiovascular stress using automated impedance cardiography. Journal of Clinical Pharmacology. Jan. 1997;37(1 Suppl):21S-28S. [pmid: 9048281].
Shoemaker WC, Wo CC, Chan L, et al. Outcome prediction of emergency patients by noninvasive hemodynamic monitoring. Chest. Aug. 2001;120(2):528-537. [pmid: 11502654].
Shoemaker WC, Wo CC, Yu S, et al. Invasive and noninvasive haemodynamic monitoring of acutely ill sepsis and septic shock patients in the emergency department. Eur J Emerg Med. Sep. 2000;7(3):169-175. [pmid: 11142267].
Shoemaker WC, Belzberg H, Wo CC, et al. Multicenter study of noninvasive monitoring systems as alternatives to invasive monitoring of acutely ill emergency patients. Chest. Dec. 1998;114(6):1643-1652. [pmid: 9872201].
Shoemaker WC, Wo CC, Bishop MH, et al. Multicenter trial of a new thoracic electrical bioimpedance device for cardiac output estimation. Crit Care Med. Dec. 1994;22(12):1907-1912. [pmid: 7988125].
Spiess BD, Patel MA, Soltow LO, et al. Comparison of bioimpedance versus thermodilution cardiac output during cardiac surgery: evaluation of a second-generation bioimpedance device. J Cardiothorac Vasc Anesth. Oct. 2001;15(5):567-573. [pmid: 11687996].
Springfield C, Sebat C, Sebat, et al. Utility of impedance cardiography (BioZ ICG) in the emergency department to evaluate patients with dyspnea and symptomatic hypotension. Am College of Emerg Physicians annual meeting abstracts. Ann Emerg Med. 2002. Pt 2 40(4).
Stetz CW, Miller RG, Kelly GE, Raffin TA. Reliabillity of the thermodilution method in the determination of cardiac output in clinical practice. Am Rev Respir Dis. 1982;126:1001-1004. [pmid: 6758640].
Summers RL, Bradley K, Piel CP, et al. Myocardial oxygen consumption in patients with acute cocaine intoxication. Acad Emerg Med. May. 2001;8(5):559.
Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-analysis in Medical Research. New York. John Wiley and Sons. 2000.
Taler SJ, Textor SC, Augustine JE. Resistant hypertension: comparing hemodynamic management to specialist care. Hypertension. May. 2002;39(5):982-988. [pmid: 12019280].
Tate P, Seeley RR, Stephens TD, editors. Understanding the Human Body. St. Louis. Mosby. 1994.
Tatevossian RG, Shoemaker WC, Wo CC, et al. Noninvasive hemodynamic monitoring for early warning of adult respiratory distress syndrome in trauma patients. J Crit Care. 2000;15(4):151-159. [pmid: 11138876].
Thangathurai D, Charbonnet C, Roessler P, et al. Continuous intraoperative noninvasive cardiac output monitoring using a new thoracic bioimpedance device. Journal of Cardiothoracic & Vascular Anesthesia. Jun. 1997;11(4):440-444. [pmid: 9187992].
Thomas AN, Ryan J, Doran BR, et al. Bioimpedance versus thermodilution cardiac output measurement: the Bomed NCCOM3 after coronary bypass surgery. Intensive Care Medicine. 1991;17(7):383-386. [pmid: 1774390].
Thomas SH, Crowther A. Impedance cardiography during exercise in patients with coronary heart disease. Eur Heart J. Feb. 1993;14(2):150-159. [pmid: 8449190].
Thomas SH. Impedance cardiography using the Sramek-Bernstein method: accuracy and variability at rest and during exercise. Br J of Clin Pharmacology. Dec. 1992;34(6):467-476.
Trupp RJ, Voegtlin L, Abraham WT, et al. Transthoracic impedance cardiography for optimization of inter-ventricular timing during cardiac resynchronization therapy. Annual Scientific Sessions of N Am Soc Pacing and Electrophysiol abstracts. Pacing Clin Electrophysiol. 2002;25(4). Pt. II: 609.
van der Meer BJ, Vonk NA, Bax JJ, et al. Non-invasive evaluation of left ventricular function by means of impedance cardiography. Acta Anaesthesiol Scand. Feb. 1999;43(2):130-134. [pmid: 10027018].
van der Meer BJ, de Vries JP, Schreuder WO, et al. Impedance cardiography in cardiac surgery patients: abnormal body weight gives unreliable cardiac output measurements. Acta Anaesthesiol Scand. Jun. 1997;41(6):708-712. [pmid: 9241329].
van der Meer BJ, Woltjer HH, Sousman AM, et al. Impedance cardiography. Importance of the equation and the electrode configuration. Intensive Care Medicine. Oct. 1996;22(10):1120-1124. [pmid: 8923081].
van der Meer NJ, Vonk NA, Kamp O, et al. Noninvasive measurement of cardiac output: two methods compared in patients with mitral regurgitation. Angiology. Feb. 1999;50(2):95-101. [pmid: 10063939].
van der Meer NJ, Oomen MW, Vonk NA, et al. Does impedance cardiography reliably estimate left ventricular ejection fraction?. Journal of Clinical Monitoring. Jan. 1996;12(1):5-9. [pmid: 8732810].
Velmahos GC, Wo CC, Demetriades D, et al. Invasive and noninvasive hemodynamic monitoring of patients with cerebrovascular accidents. Western Journal of Medicine. Jul. 1998;169(1):17-22. [pmid: 9682626].
Weinhold C, Reichenspurner H, Fulle P, Nollert G, Reichart B. Registration of thoracic electrical bioimpedance for early diagnosis of rejection after heart transplantation. J Heart Lung Transplant. 1993;12:832-836. [pmid: 8241224].
Weiss S, Calloway E, Cairo J, et al. Comparison of cardiac output measurements by thermodilution and thoracic electrical bioimpedance in critically ill versus non-critically ill patients. Am J Emerg Med. Nov. 1995;13(6):626-631. [pmid: 7575799].
Woltjer HH, Bogaard HJ, Bronzwaer JG, et al. Prediction of pulmonary capillary wedge pressure and assessment of stroke volume by noninvasive impedance cardiography. Am Heart J. Sep. 1997;134(3):450-455. [pmid: 9327701].
Woltjer HH, Bogaard HJ, van der Spoel, de Vries PM. The influence of weight on stroke volume determination by means of impedance cardiography in cardiac surgery patients. Intensive Care Med. Aug. 1996a;22(8):766-771. [pmid: 8880245].
Woltjer HH, Bogaard HJ, Scheffer GJ, et al. Standardization of non-invasive impedance cardiography for assessment of stroke volume: comparison with thermodilution. Br J Anaesth. Dec. 1996b;77(6):748-752. [pmid: 9014628].
Wong DH, Onishi R, Tremper KK, et al. Thoracic bioimpedance and Doppler cardiac output measurement: learning curve and inter-observer reproducibility. Crit Care Med. 1989;17(11):1194-1198. [pmid: 2791600].
Wong KL, Hou PC. The accuracy of bioimpedance cardiography in the measurement of cardiac output in comparison with thermodilution method. Acta Anaesthesiol Sin. Jun. 1996;34(2):55-59. [pmid: 9084523].
World MJ. Methods of estimating cardiac output in the field. QJM. Jun. 1996;89(6):457-462. [pmid: 8758049].
Yakimets J, Jensen L. Evaluation of impedance cardiography: comparison of NCCOM3-R7 with Fick and thermodilution methods. Heart & Lung. May. 1995;24(3):194-206. [pmid: 7622393].
Young C, Smart FW, Ventura HO. Difficult cases in heart failure: Atrioventricular interval optimization utilizing thoracic electrical bioimpedance. Congest Heart Fail. Sep–Oct. 1999;5(5):235-237. [pmid: 12189306].
Young JD, McQuillan P. Comparison of thoracic electrical bioimpedance and thermodilution for the measurement of cardiac index in patients with severe sepsis. Br J Anaesth. Jan. 1993;70(1):58-62. [pmid: 8431335].
Yung GL, Fletcher CC, Fedullo PF, et al. Non-invasive cardiac index using bioimpedance in comparison to direct fick and thermodilution methods in patients with pulmonary hypertension. Abstract. Chest. Oct. Suppl. 1999;116(4):281S.
Zacek P, Kunes P, Kobzova E, et al. Thoracic electrical bioimpedance versus thermodilution in patients post open-heart surgery. Acta Medica (Hradec Kralove). 1999;42(1):19-23. [pmid: 10566176].
Zemel MB, Gualdoni SM, Sowers JR. Reductions in total and extracellular water associated with calcium-induced natriuresis and the antihypertensive effect of calcium in blacks. Am J Hypertens. Jan. 1988;1(1):70-72. [pmid: 3285859].
Zerahn B, Jensen BV, Olsen F, et al. The effect of thoracentesis on lung function and transthoracic electrical bioimpedance. Respir Med. Mar. 1999;93(3):196-201. [pmid: 10464878].
Zubarev M, Dumler A, Shutov V, et al. Assessment of left ventricular systolic function and diastolic time intervals by the bioimpedance polyrheocardiographic system. Ann N Y Acad Sci. Apr. 20. 1999;873:191-196. [pmid: 10372168].