# Non-comparison Studies

Evidence Table 2 Non-comparison Studies: Part I

Evidence Table 2 Non-comparison Studies: Part II