# Comparison Studies

Evidence Table 1 Comparison Studies: Part I

Evidence Table 1 Comparison Studies: Part II

Evidence Table 1 Comparison Studies: Part III