# CONCLUSION

The clinical reports on the use of TEB for a variety of clinical indications by reports published since 1991 suggested that this non-invasive method is of interest and may potentially support some of these indications, but there is little evidence that directly addressed how this monitoring technique can affect patient outcomes. A conceptual model that captures the essential clinical aspects of the use of this technique for clinical management and therapeutics, such as the CMS analytic model described in the Introduction, will aid the design of such studies.

There was little conclusive evidence regarding TEB’s usefulness in the specific areas addressed, and this was largely due to the lack of focus of researchers in this area on clinical outcomes. One study (Taler, Textor, Augustine, et al., 2002) is an example of the type of study that needs to be done; it evaluated the use of TEB for managing patients with resistant hypertension and examined hypertension, an important outcome, that is a well-accepted surrogate for other important health outcomes. The Taler, Textor, Augustine, et al. (2002) study demonstrates the importance of a control group. In that study patients in the TEB and the control group both experienced large reductions in blood pressure; therefore, the majority of the effect in the study is attributed to other factors that are common to both the control group and the intervention group such as access to the expert specialists. The results may not be generalizable in a community setting.

In conclusion, using the Fineberg, Bauman, Sosman et al. criteria described above, the following table summarizes TEB performance based on available studies:

FINEBERG, BAUMAN, SOSMAN ET AL. CRITERION | TEB Performance
Technical capacity (feasibility and reproducibility) | Variable results
Diagnostic accuracy (test performance, i.e. sensitivity, specificity) | Insufficient data
Diagnostic impact (influence on the pattern of subsequent diagnostic testing and replacement of other test or procedures) | Insufficient data
Therapeutic impact (influence the selection and delivery of therapy), and | Insufficient data
Patient outcome (contribution to improved health). | Insufficient data