# DISCUSSION

Fineberg, Bauman, Soman et al. (1977) suggested five criteria for evaluating diagnostic technologies:

- Technical capacity (feasibility and reproducibility),
- Diagnostic accuracy (test performance, i.e. sensitivity, specificity),
- Diagnostic impact (influence on the pattern of subsequent diagnostic testing and replacement of other tests or procedures)
- Therapeutic impact (influence the selection and delivery of therapy), and
- Patient outcome (contribution to improved health).

The majority of the studies on TEB address only the first issue, technical capacity. One study on heart transplant patients addressed the second issue, sensitivity and specificity for diagnosing a specific condition (in this case rejection of the transplant); but this study did not quantify the potential diagnostic impact, therapeutic impact or patient outcome. One study on the use of TEB in resistant hypertension addressed the fifth issue, patient outcome compared to a standard treatment (in this case management by a specialist).

While we did not conduct a systematic review of other diagnostic tests, several additional reports regarding TD are relevant. One systematic review of 1,610 patients from 12 randomized controlled trials “ …examined the incidence of major morbidity in critically ill patients managed with pulmonary artery catheters … and found a statistically significant reduction in morbidity using pulmonary artery catheter-guided strategies…” (Ivanov, Allen, Calvin, 2000). In contrast, another review (of studies of less ill patients) of four randomized prospective studies found that “…in moderate risk vascular surgery patients routine preoperative pulmonary artery catheterization is not associated with improved outcomes…” (Barone, Tucker, Rassias, et al., 2001).

It should also be noted that the parameter most useful in patient management obtained from catheterization is pulmonary artery wedge pressure, which cannot be directly measured by TEB. Furthermore, Drazner, Thompson, Rosenberg, et al. (2002) found that thoracic fluid content obtained via TEB did not correlate well with this cardiac parameter.

There has been considerable debate about the value of right heart catheterization (using TD), with concern not only about lack of demonstrated benefit, but also about possible harm. Potential reasons that have been suggested to explain negative outcome include complications of the procedure itself or, possibly harmful, aggressive interventions (e.g. inotropic therapy) initiated in response to catheterization findings. (Connors, Speroff, Dawson et al., 1996; Hall, 2000; Polanczyk, Rohde, Goldman et al., 2001). One review concluded that inotropic (e.g. dobutamine, milrinome) therapy has “… beneficial hemodynamic effects…” (Felker and O’Connor, 2001). These authors, however, also described a “negative impact on survival in patients with heart failure” and concluded that the evidence for the impact of this type of therapy on improving quality of life is “mixed”.

This debate about TD is only indirectly related to the key objective of this TA of evaluating the use of TEB. It warrants consideration, however, because evaluating TEB using existing literature requires comparison to TD, since much of the literature compares TEB to thermodilution in inpatient and intensive care unit settings. Due to the extensive use of TD implied by the large number of comparisons, the accuracy of TEB relative to TD is relevant. The controversy about the value of TD (beyond the issue of its accuracy) results from outcomes studies of that procedure. The fact that outcomes studies raise these issues strengthens the point made repeatedly in this TA --- without more such studies of TEB, conclusions about its usefulness in patient care must remain limited.

The most important limitation in addressing the questions raised in this review is the almost complete absence of studies examining clinical outcomes in a methodologically sound manner. It is for this reason that each of the Results sections repeatedly emphasizes this. This limits the interpretation of the quantitative and non-quantitative results that follows. Additionally, as mentioned previously, many of the studies reviewed have serious methodological flaws beyond this basic one.

First, to best evaluate diagnostic test performance, comparisons of one test versus another should be made on each test’s ability to diagnose a specific clinical condition. Studies that take this approach are almost non-existent, so a sound answer to the study question regarding this issue is impossible to provide. We therefore had to rely solely on comparisons of TEB to various other tests, and this presented another problem. The Fick method is, in a sense, a “gold standard” but is not and cannot be commonly used in outpatient practice. In fact, none of the tests commonly used in actual practice are likely to qualify as a gold standard, and their usefulness could only be assessed by a systematic review of those other tests.

Another review article attempts to address this problem. Critchley and Critchley (1999) quotes the accuracy of TD as +/− 10 to 20%, and suggests that +/− 20 to 30% limits of agreement would be acceptable for patients with certain indications. While our review was not designed to estimate the prevalence of the use of this alternative technique, TD was the most frequently used comparative technique in the literature. Our meta-analyses therefore heavily rely on this technique for most comparisons.

Correlation coefficients are poor summary indicators of the relative performance of diagnostic tests. At least one researcher (Critchley and Critchley, 1998) describes their use as ‘inappropriate.’ Interpreting the correlation coefficient is complicated further by the difficulty in translating its magnitude into a clinically meaningful statement. While the scope of this review did not include a review of how comparison techniques compare among themselves on this measure, we do have limited information which may help to put the correlation results into context. For example, Handelsman (1992) reported that the correlation of TD with Fick ranged from .89 to .96, but that “ … intra-subject TD measurements, depending on the clinical situation, is stated to be in the range of 15% to 20%…” or even higher during mechanical ventilation.

Looking at TEB performance within subgroups is clinically more meaningful than combining coefficients across the various cardiac metrics, equations, and practice settings. This approach, however, trades off the higher statistical power that would result from collapsing across some of these categories. Correlations as high as .879 for TD measurement of cardiac output compared to TEB using the Sramek-Bernstein equation appear encouraging, but the wide confidence interval (.642 - .962) based on only three studies limits the inferences that can be made. Similarly, the low correlation of .349 (.122 to .541) for CI using the Sramek–Bernstein equation is tempered by the scarcity of data. In summary, there is great variability in the results reporting correlation coefficients.

Critchley and Critchley (1999) point out that with their data, for one subset of patients, the difference between TD and TEB is not much greater than the difference between different measurements of TD itself. That paper also points out that the repeatability of bioimpedance is 4 to 8%--better than TD.

A better measure than correlation coefficients (Critchley and Critchley, 1999; Bland and Altman, 1986) is the “bias” and limits of agreement. We, like Critchley and Critchley, found that the bias is infrequently reported, and when present, it is sometimes based on inappropriate measurements. The three studies with the largest bias in cardiac output (Balestra, Malcrida, Leonardi et al., 1992; Ng, Coleman, Walley, et al., 1993); Critchley, Calcroft, Tan, et al., 2000) shared a common characteristic. These authors used only a single measurement or averages of the multiple measurements without controlling for the variability of the measurements. Lack of controlling for the variability of TD measurements may be one explanation for these results (Stetz, Miller, Kelly, et al., 1982).

Nonetheless, we did identify 12 articles (thirteen studies) for which the measurement method justified further analysis. The implications of these results depend upon the “clinical interpretability” of the limits of agreement. It is difficult to interpret such results, however, without data on clinical outcomes. In addition, the issue of the adequacy of the reference “standard” (in this instance TD) remains in doubt.

Finally, the scarcity of suitable data placed limits on what could be quantitatively analyzed. For example, combinations of equations and electrode configurations, which some of the studies suggested may be important, were not analyzed.