# PREVIOUS SYSTEMATIC REVIEWS

Five systematic reviews (Fuller, 1992; De Maria and Raisinghani, 2000; Handelsman, 1992; Raaijmakers, Faes, Scholten, et al., 1999; Critchley and Critchley, 2000) have examined whether the measurement of cardiac output by TEB is comparable to measures obtained by other technologies. The conclusions reported in these systematic reviews are summarized below:

Fuller (1992):

- “…A moderately good correlation exists between impedance cardiac output measurement and other techniques, although correlation is not so good when ICU patients are studied…”

Raaijmakers, Faies, Scholten et. al. (1999):

- “ …The overall r^2^ value of .67 indicates that thoracic impedance cardiography might be useful for trend analysis of different groups of patients. However, for diagnostic interpretation, a value of .53 might not meet the required accuracy of the study…Great care should be taken when thoracic impedance cardiography is applied to the cardiac patient…”

De Maria and Raisinghani (2000):

- “…impedance cardiography has the potential to make routine assessment and trending of cardiac output a viable alternative to assist in the management of both chronically and acutely ill patients, including those with heart failure…”

Critchley and Critchley (1999):

“…Using our revised criteria for the acceptance of limits of agreement of less than +/− 28.3%, the results of many of the studies performed in the early 1990’s using Doppler ultrasound and bioimpedance methods would still support the rejection of either of the newer techniques in favor of TD. This is particularly true of studies involving impedance cardiography in critically ill patients… however apart from this specific <critical care> situation our present review of the literature suggests that the bioimpedance method is more accurate than current Doppler techniques….” They conclude by suggesting technological improvements be made to improve the accuracy of both.