# FURTHER CONSIDERATION OF CERTAIN RELEVANT ABSTRACTS AND OTHER MATERIAL

For some of the indications and some of the material discussed in the Results section, some additional material beyond that previously presented merits comment. In this section we mention several abstracts, none of which appear to have been published as full articles (the earliest was first presented in 1998). It is difficult to adequately evaluate these reports, because this type of publication provides limited information. They are included, however, to provide relevant information about work in progress.

## 4.1 Comparisons to alternative technologies for monitoring

Several abstracts that could not be evaluated for the reasons described above involved comparisons of TEB to alternative techniques. Yung, Fletcher, Fedullo, et al. (1999) reported comparing TEB to TD and Fick on 33 ambulatory patients with echocardiographic evidence of pulmonary hypertension. Based on the correlation coefficients and measures of bias and precision against TD and Fick that they obtained, the authors suggested that, for measuring CI in patients with pulmonary hypertension, TEB may be a convenient, less costly alternative to TD.

An abstract by Milzman, Napoli, Gerace et al. (2000) reported studying whether the use of TEB monitoring of 58 heart failure patients in the ED (stratified by whether or not their CI improved after one hour of therapy in the ED) affected total hospital stay and charges. They concluded that TEB was helpful identifying patients likely to show an early response to therapy and to incur lower total costs, but they also observed that the device had limitations when certain arrhythmias occurred and that the lack of central pressure monitoring could be problematic.

In another abstract Kzanegra, Barcarse, Chen et al. (2002) reported investigating whether TEB measurements, combined with knowledge of B-type natriuretic peptide (BNP) levels, improved physicians’ ability to diagnose congestive heart failure (CHF) in 98 patients in an emergency setting. They concluded that TEB enabled better diagnosis of CHF by rapidly distinguishing systolic from diastolic dysfunction and by assessing severity of illness.

## 4.2 Acute Dsypnea

Diagnosing the cause of dyspnea can be difficult and TEB has been proposed as a tool that is potentially useful for the differential diagnosis of cardiogenic and pulmonary causes of dyspnea in an abstract by Marrocco, Eskin, Nashed et al. (1998). They studied the sensitivity and specificity of hemodynamic parameters measured by TEB to distinguish between cardiogenic and pulmonary causes of dyspnea. Only patients with "clinically clear" diagnoses were included, and only moderate sensitivity and specificity were achieved with TEB. This suggests that the diagnostic performance of TEB would be unacceptable when all patients are considered, including patients with mixed or uncertain diagnoses that were excluded from this study. Since this report was in abstract form, it is impossible to assess the quality of the study and its usefulness.

No studies on the use of TEB for differential diagnosis of dyspnea were found in a search of Medline^®^. This search was supplemented with a search for abstracts published at the annual meetings of the American Academy of Emergency Medicine. Two relevant abstracts presented in the last three years were found, and a reviewer suggested an additional abstract. Han, Lindsell, Tsurov et al. (2002) found a significant correlation in hemodynamic parameters measured by TEB in the presence of congestive heart failure as determined by follow-up over the next two months, but no information was given about whether the use of TEB would lead to changes in management. Another abstract (Aisiku, Ander, Knoepp et al., 2000) did not find a correlation between hemodynamic parameters measured with TEB and subjective improvement in dyspnea following treatment for heart failure. These studies suggest that changes in hemodynamic parameters may be measured in patients with dyspnea, but the interpretation and clinical utility of these measurements is not known at the present time. The abstract suggested by the reviewer described a study of 45 dyspneic and hypotensive patients in which TEB was compared with an ED physician’s clinical judgment to determine whether the cause of the dyspnea and hypotension was cardiogenic (Springfield, Sebat, and Sebat, 2002). The authors concluded that TEB yielded a quicker assessment and equal accuracy, which could enable earlier intervention. Again, since these reports were in abstract form, it is impossible to assess their quality and usefulness.

## 4.3 Atrioventricular Delay

A narrative review article by Belott (1999) asserted that finding the optimal AV delay is valuable to maximize cardiac output and prevent mitral regurgitation, but that most pacemakers are left at the default setting because of the difficulty of finding the optimum value. The article also stated that newer pacemakers have internal systems that work on a similar principle to bioimpedance (minute ventilation) for automatic parameter adjustment, but that possibly harmful interactions can occur with these systems and TEB, so TEB would be contraindicated for patients with these pacemakers.

The proposed benefit of TEB is based on an analytic framework with three steps:

1. TEB can measure changes in cardiac output in response to programming changes in the AV delay in pacemakers.
2. The optimal AV delay can be found based on the information provided by TEB.
3. Adjusting the AV delay would potentially improve clinical outcomes.

The Ovsyshcher, Gross, Blumberg (1992) article cited above only addressed the first part of this analytic framework (without a confirmatory technique). The Ovsyshcher, Gross, Blumberg (1993b) article addressed the second, but did not have any independent confirmation (such as echocardiogram) that the values found were objectively optimal. The Kindermann, Frohlig, Doerr et al. (1997) study is a step in this direction.

In another abstract related to this subject that was suggested by a reviewer, Trupp, Voegtlin, Abraham et al. (2002) studied 15 patients before discharge to determine whether TEB could better determine optimal inter-ventricular settings during biventricular pacing than echocardiography. The results presented by these authors were unclear, although they concluded that TEB “…may provide an alternative noninvasive method to echo…”

Finally, one case study has been reported where a single patient had resolution of symptoms of heart failure after optimization of atrioventricular delay with TEB (Young, Smart, and Ventura, 1999). The currently available evidence, however, is not adequate to demonstrate a benefit in health outcomes with the use of TEB.

## 4.4 Intravenous Inotropes

There were no original studies that directly addressed TEB’s usefulness for this indication. One author, however, argued in a case report for the use of TEB for this indication (Lasater, 1999), but rigorous studies of TEB for this application are needed.

## 4.5 Cardiac Patients With a Need for Fluid Management

With respect to use for congestive heart failure, the American College of Cardiology and American Heart Association in their 2001 “ACC/AHA Guidelines for the Evaluation and Management of Chronic Heart Failure in the Adult” (ACC website: http://www.acc.org/clinical/guidelines/failure/iii%5Fassessment.htm) makes the following statement about TEB for use in patients with chronic heart failure:

“…Although hemodynamic measurements can also be performed by non-invasive methods such as transthoracic bioimpedance, routine use of this technology cannot be recommended at the present time because the accuracy of bioelectrical parameters has not been defined in patients with chronic HF and it has not been shown to be more valuable than routine tests, including the physical examination. Moreover, it is not clear whether serial noninvasive hemodynamic measurements can be used to gauge the efficacy of treatment or to identify patients most likely to deteriorate symptomatically during long-term follow-up …”

## 4.6 Adverse Events

TEB does not require the skills and expertise needed for the use of invasive techniques, and only one study reported a death due to pacemaker malfunction associated with TEB use (Critchley, 1998). It is unclear, however, whether such information would have been routinely reported in these types of studies, but the FDA MAUDE database (voluntary adverse event reporting) indicated no reports related to TEB.

## 4.7 Lead Placement and Equations

Additional comments about lead placement are merited. Although they do not present evidence for their observation, Castor, Klocke, Stoll, et al. (1994) point out that small changes in the position of TEB electrodes impact measurement of cardiac output by as much as 10 percent. They suggest that decreased distance leads to overestimation of cardiac output and vice versa. These authors further suggest that “…incorrect input of height and weight of the patient in the computerized system…” can lead to error. They provide theoretical but not empirical evidence for this assertion.

While the lead placements described in the results were those most frequently encountered in this review, Critchley (1998) mentions that new electrode placement schemes have been proposed. He also mentions that the esophageal probe method described by Balestra, Malacrida, Leonardi, et al. (1992) was withdrawn because of “…fears of oesophaeal perforation with surgical diathermy and defibrillation.” However, no specific reference was provided.

We report above that Demeter, Parr, Toth et al. (1993) inferred that the Kubicek equation performs well when the resistivity term is calculated from measured hematocrit rather than from an assumed constant. Fuller’s (1992) TEB review also indicated that previous studies had found improved correlations when calculated hematocrit was used. In contrast, Handelsman’s 1992 review referred to Sramek’s removal of the blood resistivity term from the Kubicek equation and characterization of this parameter as inconsequential in the context of total resistivity. Similarly, in a study of cardiac output among nineteen patients with chronic obstructive pulmonary disease, Bogaard, Hamersma, Horsch, et al. (1997) concluded that measured hematocrit resulted in only a small improvement in validity. These contrasting findings raise the issue of whether more research on this issue may be needed.

The reporting of equations in studies reviewed was not always complete, and for some devices the equations may be proprietary by the manufacturer of the device and not known to the researcher. For example, three recent studies with a total of 95 patients (Spiess, Patel, and Soltow, 2001; Drazner, Thompson, Rosenberg, et al., 2002; Sageman, Riffenburgh, and Spiess, 2002) reported using "BioZ" equipment (Cardiodynamics International Corporation, San Diego, CA), but these studies did not describe which equation was used. The correlation coefficients measured in these three studies range from 0.61–0.93. The combined correlation coefficient for these three studies is r=0.788; 95% CI: 0.466–0.926; which is somewhat higher than the correlation coefficient we calculated only for studies which indicated that the Sramek-Bernstein equation was used. These three studies illustrate the large number of variables between the studies that make it difficult to combine the studies in a single meta-analysis (see Evidence Table I for details). For example, in one study patients are critically ill but in another patients are hospitalized but not critically ill.

Furthermore, the different studies measure different hemodynamic parameters. In this technology assessment, we present results of separate meta-analyses for patient setting, hemodynamic parameter measured, equation used and quality of thermodultion measurements; these meta-analyses show that there is significant between-study heterogeneity, suggesting that many other factors in addition to the factors that we have identified from the studies are important. Further studies are needed to identify all the sources of heterogeneity in TEB measurements --- especially studies that characterize the performance of TEB in the outpatient population of interest for the questions addressed in this technology assessment.

## 4.8 Electrical Disturbance

Balestra, Malacrida, Leonardi et al. (1992) observed that “… simultaneous measurement of TEB and Doppler ultrasound leads to prolonged disturbance of the impedance signal…” They explained that the Doppler transducer absorbs a large portion of the current, reducing the signal and thereby decreasing the cardiac output measurement. This effect was not mentioned in other articles, but if confirmed, it does raise concerns about simultaneous Doppler vs. TEB comparisons.

## 4.9 Manufacturers

Figure 3.4 shows correlation coefficients for cardiac output as measured by TEB for the different manufacturers’ instruments, showing results for critically ill patients (including CCU, ICU and critically ill inpatients), inpatients who were not identified as critically ill, and outpatients.

Figure 3.4 TEB Correlation Coefficients for Cardiac Output by Manufacturer

Figure 3.4 TEB Correlation Coefficients for Cardiac Output by Manufacturer

The majority of the studies were done on the NCCOM device (#9), which is no longer commercially produced. There is wide variation in the correlation coefficient measured with this device, which is no longer commercially produced. The manufacturers attribute the variation to problems with the signal processing algorithms (letter to CMS). Other possible causes of the variation include factors that are identified in the TA, such as specifics of lead placement and clinical characteristics (overweight, pulmonary embolism) that affect accuracy of the devices or other factors that have not been studied.

There is wide variation in the results across the instruments. Several factors could account for this such as variation in lead placement and clinical characteristics. The variation could also be due to differences in instrument performance; however, not enough data is available on any one instrument except the NCCOM to draw conclusions about this. Unfortunately, most of the research literature focuses on machines no longer made, and there are few data available on currently manufactured devices.