# RESULTS

In this section we address the issues raised by the key study questions described in the Introduction. We organize the questions around the seven clinical indications:

1. hemodynamic monitoring
2. acute dyspnea
3. pacemakers
4. inotropic therapy
5. heart transplants
6. fluid management
7. hypertension

Within each indication, we examine evidence regarding:

1. Clinical impact on patient management and/or improved health outcomes from the use of TEB,
2. TEB performance compared to alternative technologies for monitoring cardiac output, cardiac index, and stroke volume,
3. TEB performance compared to alternative technologies for the measurement of other physiologic parameters,
4. Factors that may affect performance of the measurement (e.g. lead placement, operator experience, comorbid conditions)
5. Potential limitations in the use of the technology relating to the setting (i.e. inpatient, outpatient, emergency), and
6. Training needs.

## 3. 1 INDICATION 1: Demonstration of changes in patient management and/or improved health outcomes from the use of the device for noninvasive diagnosis or monitoring of hemodynamics in patients with suspected or known cardiovascular disease

### 3.1.1 Clinical impact on patient management and/or improved health outcomes from the use of TEB

No studies provided information on health outcomes, patient management, or on clinical end-points to address the usefulness of TEB in monitoring or management. In what follows, however, we discuss results of studies that indirectly offer some insight into the potential uses of TEB.

Three non-comparative studies investigated uses of TEB monitoring in patients with cardiovascular and/or pulmonary disease and related complications (Greenberg, Hermann, Pranulis, et al., 2000; Scherhag, Pfleger, de Mey, et al., 1997; Zerahn, Jensen, Olsen, et al., 1999). These were preliminary studies designed to measure ranges of values and reproducibility of TEB in specific clinical populations.

Zerahn, Jensen, Olsen, et al. (1999) aimed to determine the relationship between improvement in lung function and changes in TEB after thoracocentesis in patients with pleural effusions due to heart failure or malignancy. They found that the relative impedance at baseline was twice as high in patients with cancer as compared with that in heart failure patients. They also found correlation between TEB and the "drying effect" of lung fluid aspiration in respiratory functional variables (FEV1, FVC, VC, TLC). Baseline impedance measurements did not change at the end of thoracocentesis and ten minutes later.

Greenberg, Hermann, Pranulis, et al. (2000) found that TEB provided reproducible hemodynamic measurements in the outpatient setting in 62 ill patients with clinically stable heart failure, with no reporting of adverse reactions on the procedures associated with TEB. Scherhag, Pfleger, de Mey, et al. (1997) reported on the computerized impedance cardiographic monitoring of 50 outpatients with suspected coronary artery disease (CAD) during pharmacological stress testing with dobutamine or dipyridamole. The researchers found varying responses of the hemodynamic parameters to the different pharmacologic agents, but no comparative test was used to validate this data.

Kasznicki and Drzewoski (1993) performed a study to compare the effect of chemotherapy on cardiac indices in 30 patients with hematological malignancies divided into two groups ---those with and those without cardiac risk factors. They found that chemotherapy had some effect on some hemodynamic parameters in some patients, but these measurements were not validated through comparison with other methods. Finally, it should be noted that one of the electrodes was placed on the forehead.

While the following two studies were not as directly relevant to the hemodynamic indication as the others, they are nonetheless included because they reported some hemodynamic data. Raaijmakers, Faes, Meijer, et al. (1998) investigated the effects of non-cardiogenic edema (accumulation of protein and extracellular fluid) on thoracic impedance. One study component involved 13 ICU patients with acute respiratory failure and found a poor correlation (r = −0.24) between single frequency impedance measurement and extravascular lung water measured by the double indicator dilution method. These findings may be applicable to the differential diagnosis of cardiogenic versus non-cardiogenic pulmonary edema where extravascular lung water volumes may differ. These results, however, are very preliminary and were derived from a very small heterogeneous sample of patients.

Tatevossian, Shoemaker, Wo et al. (2000) performed an uncontrolled, observational study in a series of consecutive trauma and ICU patients to evaluate whether early noninvasive monitoring using TEB may reveal early circulatory deficiencies that lead to the development of acute respiratory distress syndrome (ARDS). They used both invasive (pulmonary thermodilution catheter) and non-invasive (TEB) methods to record the time course of hemodynamic and tissue perfusion patterns in 60 severely injured postoperative patients to assess hemodynamic parameters in survivors and non-survivors of ARDS. In a subgroup analysis they observed significantly lower cardiac index and transcutaneous oxygen tension, and higher transcutaneous carbon dioxide tension beginning with the early stage in those patients who developed ARDS compared with those who did not. They concluded that early noninvasive monitoring in the emergency department, operating room, and ICU can disclose patterns of reduced cardiac and tissue perfusion in patients who subsequently develop ARDS which may help identify patients at higher risk for developing ARDS, a rather strong inference, given the limitations of their study design.

These data suggest that TEB may help in the early identification of ARDS in trauma patients. This has potentially important implications in the management of ARDS and reduction of its associated morbidity and mortality.

In summary, the studies summarized in this section provide preliminary data indicating that TEB may be able to detect clinically significant changes in hemodynamic parameters in a variety of clinical situations. However, the studies do not provide adequate evidence of TEB’s clinical utility due to study design issues such as not providing a comparison group and not reporting changes in patient management and health outcomes.

### 3.1.2 TEB performance compared to alternative technologies for monitoring cardiac output, cardiac index, and stroke volume

Assessment of diagnostic performance requires information on how well a test identifies a disease or some aspect of a disease. We did not identify any studies that used TEB to diagnose a disease or condition, so in this section we can only compare ‘agreement’ between TEB and alternatives. Most of the data available on TEB report correlations with reference tests; correlation coefficients have serious limitations when used to summarize diagnostic test data. There were 49 comparisons in 45 articles that paired TEB with other techniques and reported correlation coefficients (Table 3.1; some articles contained more than one ‘study.’). The majority of these comparisons were to TD, with a small number of comparisons to the two Fick methods, echocardiogram, and radionuclide methods. The greatest amount of data were provided for the cardiac output and cardiac index metrics, with the least provided on stroke volume and left ventricular ejection fraction. The meta-analyses described below therefore focus on the comparisons of TEB cardiac output and cardiac index to TD, according to the analytic framework presented in Figure 3.1. The results are presented below for various subgroups.

Table 3.1 Summary of studies reporting correlation coefficients^*^

| Study | Ref. Test | Parameter | Setting | Equation | Manufacturer of TEB | Disease | Corr. | N | Measurement Condition
1 | Balestra 1992 | TD | CO | IN | SB | NCCOM-4 | CV | 0.74 | 10 | External electrodes
2 | Barin 2000 | TD | CO | OUT | K | Rheo-Graphic | Lab | 0.86 | 47 | Suspected cardiac disease
3 | Barry 1997 | TD | CO | IN | SB | NCCOM-3 | Mixed ICU | 0.10 | 7
4 | Belardinelli 1996a | TD | CO | OUT | SB | NCCOM-7 | CAD | 0.90 | 10 | Normal LV @exercise
| | | | | | | | 0.98 | 10 | Normal LV @rest
| 1996b | | | | | | | 0.90 | 15 | isch cardiomyo @exercise
| | | | | | | | 0.94 | 15 | isch cardiomyo @rest
5 | Clancy 1991 | TD | CO | IN | SB | NCCOM-7 | mixed ICU | 0.91 | 17
6 | Critchley 1996 | TD | CO | IN | SB | NCCOM-7 | mixed ICU | 0.60 | 8
7 | Critchley 2000 | TD | CO | IN | SB | NCCOM-7 | Sepsis | 0.39 | 24
8 | Demeter 1993 | TD | CO | IN | K | Minnesota 304B | CABG | 0.84 | 10 | Supine 1
| | | | | | | | 0.90 | 10 | 45 degrees
| | | | | | | | 0.97 | 10 | Supine 2
9 | Doering 1995 | TD | CO | IN | ND | NCCOM-3 | cardiac surg | 0.22 | 34 | Postextubation
| | | | | | | | 0.28 | 34 | Normothermia
| | | | | | | | 0.46 | 34 | 24h ICU
| | | | | | | | 0.48 | 34 | ICU admission
10 | Drazner 2002 | TD | CI | IN | ND | BioZ | heart failure | 0.64 | 50
| | | CO | | | | | 0.76 | 50
11 | Genoni 1998 | TD | CO | IN | SB | NCCOM-7 | lung injury | 0.30 | 10 | ZEEP
| | | | | | | | 0.60 | 10 | PEEP
12 | Horstmann 1993 | TD | CO | OUT | K | Diefenbach | Lab | −0.01 | 35 | at rest
| | | | | | | | 0.45 | 35 | at exercise
13 | Jewkes 1991 | TD | CO | IN | SB | NCCOM-3 | mixed ICU | 0.72 | 16
| | | SV | | | | | 0.83 | 16
14 | Marik 1997 | TD | CO | OUT | ND | Renaissance-IQ | CHD | 0.08 | 24
15 | Ng 1993 | TD | CO | IN | SB | NCCOM-7 | mixed ICU | 0.87 | 37
16 | Perrino 1994 | TD | CO | IN | SB | NCCOM-7 | noncardiac surgery | 0.84 | 43
17 | Pickett 1992 | TD | CO | IN | K | HDC | mixed ICU | 0.86 | 43 | SM with means of multiples
18 | Raaijmakers 1998a | TD | CO | IN | SB | ND | sepsis | 0.42 | 13
19 | Sageman 1993 | TD | CO | IN | SB | NCCOM-7 | CABG | 0.48 | 50
20 | Sageman 2002 | TD | CI | IN | ND | BioZ | CABG | 0.93 | 20
21 | Shoemaker 1994 | TD | CI | ED | ND | Renaissance-IQ | mixed ED | 0.86 | 68
22 | Shoemaker 1998 | TD | CI | ED | ND | Renaissance-IQ | mixed ED | 0.85 | 680
23 | Shoemaker 2000 | TD | CI | ED | ND | Renaissance-IQ | mixed ED | 0.78 | 45
24 | Shoemaker 2001 | TD | CO | ED | ND | Renaissance-IQ | mixed ED | 0.91 | 151
25 | Spiess 2001 | TD | CI | IN | ND | BioZ | CABG | 0.87 | 47 | Postanesthesia
| | | | | | | | 0.56 | 45 | Chest closed
| | | | | | | | 0.73 | 45 | Chest open
| | | | | | | | 0.76 | 47 | after bypass
26 | Thangathurai 1997 | TD | CO | IN | ND | IQ 101 | surgery | 0.89 | 23
27 | Van der Meer 1996 | TD | CO | IN | SB | IPG-104 | CABG | 0.83 | 21
28 | Van der Meer 1997 | TD | CO | IN | SB | IPG-104 | CABG | 0.60 | 37
29 | Velmahos 1998 | TD | CI | ED | ND | Renaissance-IQ | CV accidents | 0.82 | 17
30 | Weiss 1995 | TD | CO | OUT | SB | NCCOM-7 | lab | 0.69 | 15 | Stable pts
| | | | | | | MICU | 0.81 | 13 | Unstable pts
31 | Woltjer 1996b | TD | SV | IN | SB | IPG-104 | CABG | 0.64 | 37
32 | Woltjer 1997 | TD | SV | OUT | K | IPG-104 | lab | 0.69 | 24
33 | Wong KL 1996 | TD | CO | IN | SB | NCCOM-7 | CABG | 0.86 | 18
34 | Zacek 1999 | TD | CI | IN | SB | HotmanAH-HHC | cardiac surgery | 0.26 | 28
35 | Zubarev 1999 | TD | CO | IN | mod K | BPCS | AMI | 0.91 | 11
36 | Woo 1992 | TD | CO | IN | SB | NCCOM-3 | heart failure | 0.51 | 44
37 | Yakimets 1995 Tr2 | TD | CI | IN | SB | NCCOM-7 | cardiac surgery | 0.40 | 28 | 2–4h postsurgery
| | | | | | | | 0.45 | 28 | Immed postsurgery
| | | CO | | | | | 0.51 | 28 | 2–4h postsurgery
| | | | | | | | 0.55 | 28 | Immed postsurgery
38 | Young 1993 | TD | CI | IN | SB | NCCOM-6 | sepsis | 0.36 | 19
39 | Belardinelli 1996 | Dir Fick | CO | OUT | SB | NCCOM-7 | CAD | 0.93 | 15 | isch cardiomyo @exercise
| | | | | | | | 0.85 | 15 | isch cardiomyo @rest
| | | | | | | | 0.89 | 10 | Normal LV @exercise
| | | | | | | | 0.95 | 10 | Normal LV @rest
40 | Yakimets 1995 Tr1 | Dir Fick | CI | OUT | SB | NCCOM-7 | lab | 0.26 | 17 | at exercise
| | | | | | | | 0.62 | 17 | at rest
| | | SV | | | | | 0.43 | 17 | at exercise
| | | | | | | | 0.76 | 17 | at rest
41 | Drazner 2002 | Dir Fick | CI | IN | ND | BioZ | heart failure | 0.61 | 28
| | | CO | IN | ND | BioZ | heart failure | 0.73 | 28
42 | Bogaard 1997 | Ind Fick | CO | OUT | K | IPG-104 | COPD | 0.92 | 14
43 | Antonicelli 1991 | Pulsed Doppler | SV | OUT | K | ND | HBP | 0.95 | 14
44 | Van der Meer 1999 | Echo Doppler | CO | OUT | SB | IPG-104 | lab | 0.85 | 26
45 | Summers 2001 | Echo-cardiog | LVEF | ED | ND | Sorba | mixed ED | 0.89 | 15 | Capan method
| | | | | | | | 0.89 | 15 | Weissler method
46 | Bowling 1993 | Angiography | LVEF | OUT | ND | NCCOM-7 | Cancer | 0.74 | 20
47 | Marik 1997 | Angiography | LVEF | OUT | ND | Renaissance-IQ | CAD | 0.02 | 24
48 | Mattar 1991 | Angio/nucl steth | LVEF | IN | SB | NCCOM-7 | mixed ICU | 0.69 | 17
49 | Thomas SH 1992b | Angiography | CO | IN | SB | NCCOM-7 | CHD | 0.25 | 34
| | | SV | | | | | 0.65 | 34

Note: Some articles report more than one 'study.'

* Abbreviations:

TD=Thermodilution

CO=Cardiac input

CI=Cardiac Index

SV=Stroke volume

IN=Inpatient

OUT=Outpatient

ED=Emergency Dept.

SB=Sramek-Bernstein

K=Kubicek

ND=No data

### 3.1.4.1 Factors that may affect test performance (e.g. lead placement, operator experience, comorbid conditions)

Most studies did not investigate any of these factors. No studies reviewed have analyzed the influence of operator experience; TEB measurements were typically obtained as part of routine care. The evidence tables describe the co-morbidities of patients in each study. In the large majority of studies, no separate data were provided on the agreement of TEB compared with another technique for patients with a specific comorbid condition.

### 3.1.4 Leads and Equations

#### Overall Lead Positioning

The principle of TEB is based on measuring the impedance in the thorax when an alternating current is applied. Electrodes are used to apply the current and measure the impedance. Several equations, lead configurations, and combinations of equations and lead configurations have been described in the literature.

There are three principal equation types (Fuller, 1992; De Maria and Raisinghani, 2000; Handelsman, 1992). These equations can be summarized as follows:

- Kubicek’s equation was described in 1966 as part of NASA's effort to develop TEB as a non-invasive cardiac output monitoring system. The equation for estimating stroke volume uses measurements obtained from four circumferential aluminum strip electrodes, two around the neck and two around the torso (See below and Appendix 2 for electrode detail). The stroke volume is calculated as a function of the blood resistivity (hematocrit dependent), distance between electrodes, baseline thoracic impedance, ventricular ejection time, and the maximum rate of reduction of thoracic impedance during systole. The volume of electrically participating tissue is assumed to be a cylinder.
- Sramek modified Kubicek's equation in 1981 and replaced circumferential electrodes with four pairs of electrocardiogram (ECG)-type electrodes (see below and Appendix 2 for electrode detail). The volume of electrically participating tissue is assumed to be a cone; parameters in the equation include circumference of the thorax and the average distance between sensing electrodes, while the blood resistivity variable was eliminated.
- Bernstein (Sramek-Bernstein) modified the Kubicek and Sramek equations in 1986 by correcting for both height and weight.

Several electrode configurations linked to the equations are described by van der Meer, Woltjer, Sousman (1996):

- The original Kubicek et al. configuration used bands of circular electrodes at four levels of the thorax --- two at the neck and two just below the xyphoid. (Appendix 2)
- The lateral spot configuration consists of eight spot electrodes placed at four levels of the thorax--- two pairs inject current and two pairs measure the voltage (Appendix 2). One pair of voltage measuring electrodes is placed on the left and right mid-axillary lines at the xiphoid level. The second pair of voltage measuring electrodes is placed at the base of the neck, parallel to the first pair of measuring electrodes. The current injecting electrodes are placed on the same lines as the voltage measuring ones --- one pair is placed just below the voltage measuring electrodes at the xiphoid level, and the other pair is located just above those at the neck. This configuration is used in many currently available commercial devices.
- The semicircular spot electrode configuration consists of sixteen spot electrodes--- four pairs inject current and four pairs measure the voltage. The pattern is similar to the lateral spot placement, with two rather than four pairs of electrodes at each level. This configuration is electrically equivalent to the circular electrode configuration of Kubicek. Krasznicki and Drzewoski (1993) developed a modification of this electrode placement that included a forehead placement.

Balestra, Malacrida, Leonardi, et al. (1992) studied the accuracy of bioimpedance measurements using a prototype 7 mm diameter esophageal probe with four applied electrodes introduced via a conventional oro-gastric tube in 10 critically ill ICU patients. The use of these internal electrodes yielded high correlation (r= .989) with very little bias. The authors pointed out that this technique was less invasive than TD. It was not very practical, however, for routine use in the outpatient setting, as it was invasive and required position confirmation with radiography.

Woltjer, Bogaard, Scheffer et al. (1996) compared a modified semi-circular (MSC) array (the semicircular array with an additional current injecting electrode on the forehead with the same voltage detecting electrodes as the eight spot configuration) to the lateral spot array among patients undergoing coronary bypass surgery. They found that the Sramek-Bernstein equation was valid only with the lateral spot electrode array for calculating stroke volume, and the Kubicek equation worked well only with the modified semi-circular spot electrode array. They found a higher correlation coefficient to TD with the Kubicek equation/modified MSC electrode configuration compared to the Sramek-Bernstein/lateral spot electrode configuration.

Demeter, Parr, Toth et al. (1993) compared the estimation of cardiac output by TEB and TD in ten stable, non-ventilated male coronary artery bypass patients in an open heart recovery unit. These investigators calculated the blood resistivity for the Kubicek equation from actual hematocrits, and compared the correlation (but not bias) of cardiac output estimated from TEB vs. TD to that obtained using a ‘constant’ value. Because they found superior results using the calculated hematocrits, these investigators concluded that this approach would be most important in situations where the hematocrit is not normal, for example among the type of patients in their study.

Van der Meer, Woltjer, Sousman, et al. (1996) reported that systems using the equations which adjust for height and weight (Sramek-Bernstein and adjusted Kubicek) with the appropriate lead placement had similar performance; this performance was superior to systems using the older equations that did not adjust for height and weight (Sramek and the original Kubicek equation) in mechanically ventilated patients in intensive care settings.

There were an insufficient number of studies using similar enough equations to conduct a meta-analysis comparing equation types.

#### Effects of Electrode Type and Errors in Electrode Placement

Jewkes, Sear, Verhoeff, et al. (1991) concluded that a main source of TEB observer error “…relates to the placement of the electrodes and the electrode type… ” These authors found that different electrode types (RedDot™ and Medicotest™) resulted in significant differences in measurement of thoracic fluid index, but they did not observe significant differences in average stroke volume and cardiac output. Changing electrode position in the diagonal or frontal positions, or decreasing the effective inter-electrode position by 5 cm movement of the cervical electrodes yielded only small changes (< 5%) in thoracic fluid index and stroke volume. Large changes (39.8% increase for thoracic fluid index and 15.8% decrease for stroke volume) were observed when inter-electrode difference was increased by 10 cm.

Balestra, Malcrida, Leonardi et al. (1992) studied the effects of displacing the xiphoid voltage sensing electrodes by 3 cm in the caudal direction, which led to a change in cardiac output from 7.1 +/− 1.2 to 5.8 +/− 1.3 L/min (p< 0.001) in the lateral spot electrode configuration using Sramek-Bernstein equations in healthy volunteers (another group of critically ill ICU patients were studied in another part of this article; see above). Statistically significant increases in cardiac output were also measured when the electrodes were moved 3 and 6 cm in the cranial direction.

#### Other Factors

One study designed to investigate the influence of pulmonary edema (13 ICU patients with lung injury or adult respiratory distress syndrome) on the accuracy of cardiac output as measured by TEB found that Kubicek’s equation correlated better with TD than when the Sramek-Bernstein equation was used (Raaijmakers, Faes, Kunst, et al., 1998). These authors provided a theoretical basis for their empirical findings and postulated that Kubicek’s equation is ‘edema-independent’ due to its modeling assumptions. They also hypothesized that mechanical ventilation’s impact among patients with respiratory failure on the accuracy of TD measurements but not on those of TEB could result in measurement error being incorrectly attributed to TEB.

The performance of TEB during mechanical ventilation is also a factor of interest. Castor, Klocke, Stoll, et al. (1994) studied 10 patients with Swan-Ganz catheterization during neurosurgical removal of intracranial tumor or aneurysm. They concluded that compared to TD, TEB “… slightly overestimates cardiac output in the normal range during spontaneous ventilation and during intermittent positive pressure ventilation (IPPV)…” They reported overestimation of cardiac output in increased cardiac output states with spontaneous ventilation and underestimation of cardiac output during IPPV.

Being overweight has been suggested as a factor that might affect the performance of TEB. Van Der Meer and co-workers prospectively investigated the influence of being overweight on TEB measurements of cardiac output among forty critically ill post-cardiac surgery patients (Van der Meer, de Vries, Schreuder WO, et al., 1997). These investigators compared cardiac output measurements obtained by TEB with those obtained through the use of TD. All patients were mechanically ventilated. Three patients were excluded from the final analysis due to increased variability in cardiac output measurements obtained by the TD method and one due to dysrhythmia. In the remaining thirty-seven patients (n=37) a correlation coefficient for cardiac output of 0.60 (bias +/− 2 standard deviations = −0.06 +/− 1.25) was found between the TEB and TD methods. In a subgroup analysis the authors excluded patients with more than 15% deviation from ideal weight and calculated a correlation coefficient of 0.85 (bias +/− 2 standard deviations = 0.09 +/− 0.96) for the remaining twenty-five patients. The authors discuss potential reasons for their finding mainly in relation to the body geometry factor in the Sramek-Bernstein formula.

In another report on the same patient sample, Woltjer, Bogaard, and van der Spoel (1996) focus on stroke volume rather than cardiac output. The correlation and bias +/− 2 standard deviations was r=0.90; bias = 2.0 +/− 17.7 ml using Kubicek’s equation for normal weight patients and r=0.80; bias = −2.7 +/− 14.4 for obese patients. Using Sramek and Bernstein, the correlation and mean difference +/− 2 standard deviations was r=0.63, md= −0.8 +/− 30.8 ml and r=0.43, md= −7.7 +/− 26.2 for obese patients. In this analysis, the authors concluded that “…weight significantly influences the calculation of stroke volume when Sramek and Bernstein’s method is applied and that the weight correction factor is not valid to adjust this. Kubicek’s method, however, is not seriously biased by weight and appears to be more accurate than Sramek and Bernstein’s method in patients after coronary bypass surgery…”

Both of the above analyses suggest that larger scale investigations are needed to compare TEB with other methods in patients with abnormal anthropometric characteristics such as being overweight. The discussion of the implications of the findings about equation use adds further support to the proposition that equation type may be important.

#### Summary of Equation and Lead Placement

Many currently available commercial devices use the lateral spot electrode configuration; many devices use proprietary equations. Errors in placement of the leads and clinical factors such as patient weight and presence of pulmonary edema have been reported to affect results of measurements; data on these factors have not been adequately reported in published literature with currently available commercial devices on the outpatient population of interest.

### 3.1.5 Potential limitations relating to test performance setting (i.e. inpatient, outpatient, emergency)

#### 3.1.5.1 Correlation Coefficients

Most of the studies on bioimpedance are performed on an inpatient population; many of these patients are critically ill. Results for these patients might not be generalizable to the outpatient population of interest in this TA. In this section, we report results of separate meta-analyses for data collected in different settings.

One study directly compared TEB for measuring cardiac output between thirteen critically ill and fifteen non-critically ill patients and found no statistically significant difference in cardiac output results (Weiss, Calloway, Cairo, et al., 1995). The authors do not assess the statistical power of their design, so it is difficult to assess whether the lack of statistical significance results from true equivalence or merely lack of power. Additionally, these authors concluded that TEB measurement variability limits its use to monitoring relative changes in cardiac metrics rather than estimating absolute values of these metrics.

Table 3.2 shows meta-analyses of inpatient, outpatient, and emergency department studies comparing TEB to TD for either cardiac output or cardiac index. Since the TEB equation used might influence results, and because at least three studies was our cutoff for analysis, we restricted our analyses to studies using the Sramek-Bernstein equation. Figures 3.2.a and 3.2.b show individual study results and in what follows, when statistical significance is reported, the level was p<.0001, unless otherwise indicated. Overall (not just those studies in the meta-analysis) the correlation coefficients ranged from −0.01 to 0.97. In seventeen studies (396 patients) of cardiac output for inpatients using TD as the comparison, the combined r = 0.693 (95% CI, 0.578–0.781), with significant heterogeneity. In three studies (75 patients) of cardiac index for inpatients using TD as the comparison, the combined r = 0.349 (95% CI: 0.122–0.540), without significant heterogeneity.

Table 3.2 Combined correlation coefficients for cardiac output and cardiac index by care setting: inpatient, outpatient, emergency room (TEB compared to TD using Sramek-Bernstein equation)

| Inpatient | Outpatient | ED
Cardiac Output | .693 | .879 | -
95% Confidence Interval | .578 – .781 | .642 – .962 | -
# Studies / # Patients | 17/396 | 3/40 | -
Cardiac Index | .349 | - | .848
95% Confidence Interval | .122 – .540 | - | .827 – .866
# Studies / # Patients | 3/75 | - | 3/793

Figure 3.2.a Combined correlation coefficients for cardiac output by care setting: inpatient, outpatient, emergency room (TEB compared to TD using Sramek-Bernstein Equation) Individual Study Results

Figure 3.2.a : Combined correlation coefficients for cardiac output by care setting: inpatient, outpatient, emergency room (TEB compared to TD using Sramek-Bernstein Equation) Individual Study Results

Figure 3.2.b Combined correlation coefficients for cardiac index by care setting: inpatient, outpatient, emergency room (TEB compared to TD using Sramek-Bernstein Equation) individual study results

Figure 3.2.b: Combined correlation coefficients for cardiac index by care setting: inpatient, outpatient, emergency room (TEB compared to TD using Sramek-Bernstein Equation) individual study results

In studies of outpatients using TD as the comparison, there were three studies (40 patients) using cardiac output with combined r = 0.879 (95% CI: 0.642–0.962), without significant heterogeneity. There were no studies meeting the criteria for an analysis of outpatient cardiac index.

There were three studies (793 patients) of cardiac index in the emergency department comparing TEB to TD with combined r=0.848 (95% CI: 0.827–0.866), without significant heterogeneity. There were no studies for a meta-analysis of cardiac output in the ED.

#### 3.1.5.2 BIAS

As mentioned earlier, it is preferable to analyze the ‘bias’ and limits of agreement rather than the correlation coefficient, when they were reported and the methodology for obtaining them was correct. Of 36 studies that reported bias and limits of agreement, only 12 used the correct methodology for obtaining the data. Most comparisons were to TD, with a small number of comparisons to the direct Fick method, and only one to the pulsed Doppler method. The greatest amount of data was provided for the cardiac output metrics, with the least provided on cardiac index and stroke volume. Table 3.3 summarizes all studies reporting bias and Figure 3.2 shows the analytic framework used to analyze the bias. Due to the limited number of comparisons among outpatients, our meta-analyses focus on the test agreement between TEB cardiac output and stroke volume with TD.

Table 3.3 Summary of studies reporting bias

Study | N | Ref. Test | Test | D | SD | Unit | Measurement conditions | Replication of measurements
Antonicelli 1991 | 14 | Pulsed Doppler | SV | −0.7 | 8.5 | ml | | Yes
Atallah 1995 | 5 | TD | CI | 0.69 | 0.66 | L/min.m^2 | | Yes
Balestra 1992 | 30 | TD | CO | 1.99 | 2.20 | L/min | external electrodes | No
Barin 2000 | 47 | TD | CO | −0.18 | 0.78 | L/min | | Yes
Barry 1997 | 7 | TD | CO | −1.60 | 1.16 | L/min | | Yes
Belardinelli 1996 | 15 | TD | CO | −0.10 | 0.17 | L/min | at rest | Yes
| 15 | TD | CO | −0.12 | 0.15 | L/min | at rest 25% | Yes
| 15 | TD | CO | −0.14 | 0.20 | L/min | at rest 50% | Yes
| 15 | TD | CO | −0.16 | 0.40 | L/min | at rest 75% | Yes
| 15 | TD | CO | −0.22 | 0.22 | L/min | at rest 100% | Yes
| 10 | TD | CO | 0.04 | 0.10 | L/min | peak exercise | Yes
| 10 | TD | CO | −0.05 | 0.20 | L/min | peak exercise 25% | Yes
| 10 | TD | CO | −0.08 | 0.20 | L/min | peak exercise 50% | Yes
| 10 | TD | CO | −0.10 | 0.30 | L/min | peak exercise 75% | Yes
| 10 | TD | CO | −0.30 | 0.40 | L/min | peak exercise100% | Yes
| 15 | Fick | CO | −0.03 | 0.24 | L/min | at rest | Yes
| 15 | Fick | CO | −0.09 | 0.13 | L/min | at rest 25% | Yes
| 15 | Fick | CO | −0.12 | 0.30 | L/min | at rest 50% | Yes
| 15 | Fick | CO | −0.10 | 0.40 | L/min | at rest 75% | Yes
| 15 | Fick | CO | −0.31 | 0.42 | L/min | at rest 100% | Yes
| 10 | Fick | CO | −0.01 | 1.43 | L/min | peak exercise | Yes
| 10 | Fick | CO | −0.04 | 0.25 | L/min | peak exercise 25% | Yes
| 10 | Fick | CO | −0.02 | 0.20 | L/min | peak exercise 50% | Yes
| 10 | Fick | CO | −0.20 | 0.30 | L/min | peak exercise 75% | Yes
| 10 | Fick | CO | −0.50 | 5.53 | L/min | peak exercise100% | Yes
| 15 | TD | SV | 1.78 | 2.48 | ml | at rest | Yes
| 15 | TD | SV | 0.50 | 2.50 | ml | at rest 25% | Yes
| 15 | TD | SV | −1.10 | 3.00 | ml | at rest 50% | Yes
| 15 | TD | SV | −1.80 | 4.00 | ml | at rest 75% | Yes
| 15 | TD | SV | −3.00 | 3.40 | ml | at rest 100% | Yes
| 10 | TD | SV | 1.90 | 0.65 | ml | peak exercise | Yes
| 10 | TD | SV | 1.10 | 3.00 | ml | peak exercise 25% | Yes
| 10 | TD | SV | 0.50 | 4.00 | ml | peak exercise 50% | Yes
| 10 | TD | SV | −1.20 | 4.50 | ml | peak exercise 75% | Yes
| 10 | TD | SV | −1.97 | 0.40 | ml | peak exercise100% | Yes
Bogaard 1997 | 19 | Indir. Fick | CO | −11.7 | 11.05 | L/min | At rest | No^*^
| 10 | Indir. Fick | CO | −7.45 | 9.3 | L/min | Prior to t3 | No^*^
| 14 | Indir. Fick | CO | 3.98 | 12.8 | L/min | Prior to t4 | No^*^
| 19 | Indir. Fick | CO | 3.45 | 9.0 | L/min | Prior to t5 | No^*^
| 19 | Indir. Fick | CO | 6.85 | 8.85 | L/min | Highest work intensity | No^*^
| 19 | Indir. Fick | SV | −1.05 | 0.955 | ml | At rest | No^*^
| 10 | Indir. Fick | SV | −0.67 | 0.89 | ml | Prior to t3 | No^*^
| 14 | Indir. Fick | SV | 0.33 | 1.24 | ml | Prior to t4 | No^*^
| 19 | Indir. Fick | SV | 0.35 | 0.985 | ml | Prior to t5 | No^*^
| 19 | Indir. Fick | SV | 0.87 | 1.195 | ml | Highest work intensity | No^*^
Clancy 1991 | 17 | TD | CO | 0.23 | 0.56 | L/min | | Yes
Critchley 2000 | 24 | TD | CO | −1.49 | 2.08 | L/min | | No
Doering 1995 | 34 | TD | CI | 0.21 | 0.53 | L/min.m^2 | ICU admission | No
| 34 | TD | CI | 0.02 | 0.72 | L/min.m^2 | Normothermia | No
| 34 | TD | CI | 0.04 | 0.86 | L/min.m^2 | Postextubation | No
| 34 | TD | CI | 0.18 | 0.76 | L/min.m^2 | 24 hrs ICU | No
Drazner 2002 | 50 | TD | CI | 0.01 | 0.60 | L/min.m^2 | | No
| 28 | Fick | CI | 0.40 | 0.60 | L/min.m^2 | Subset of the 50 patients | No
| 50 | TD | CO | 0.03 | 1.10 | L/min | | No
| 28 | Fick | CO | 0.74 | 1.10 | L/min | Subset of the 50 patients | No
Genoni 1998 | 10 | TD | CO | −1.81 | 1.07 | L/min | | Yes
Hirschl 2000 | 29 | TD | CI | −0.61 | 0.74 | L/min.m^2 | | Yes
Jewkes 1991 | 16 | TD | CO | 0.86 | 0.87 | L/min | | No
| 16 | TD | SV | 13.00 | 11.10 | ml | | No
Ng 1993 | 27 | TD | CO | −1.40 | 1.40 | L/min | | No
| 27 | TD | SV | −14.00 | 13.40 | ml | | No
Perrino 1994 | 43 | TD | CO | −0.40 | 1.00 | L/min | | Yes
Pickett 1992 | 201 | TD | CO | −0.13 | 1.03 | L/min | | Yes
Raaijmakers 1998a | 30 | TD | CO | −2.40 | 2.80 | L/min | SB equation | Yes
Sageman 1993 | 50 | TD | CO | 0.33 | 1.70 | L/min | | No
Sageman 2002 | 20 | TD | CI | −0.07 | 0.20 | L/min.m^2 | | Yes
Shoemaker 1998 | 680 | TD | CI | −0.12 | 0.75 | L/min.m^2 | | Yes
Shoemaker 2000 | 45 | TD | CI | −0.16 | 0.95 | L/min.m^2 | | No
Spiess 2001 | 47 | TD | CI | −0.28 | 0.70 | L/min.m^2 | | Yes
Thangathurai 1997 | 23 | TD | CO | 0.10 | 1.00 | L/min | | Yes
Thomas AN 1991 | 28 | TD | CO | −1.08 | 0.96 | L/min | <12 hrs | Yes
| 28 | TD | CO | 0.09 | 0.54 | L/min | 12–24 hrs | Yes
Thomas SH 1992a | 15 | TD | CO | −0.55 | 0.83 | L/min | | Yes
| 15 | TD | SV | −8.10 | 13.20 | ml | | Yes
Van der Meer 1996 | 21 | TD | CO | 0.15 | 0.96 | L/min | SB equation | No
Van der Meer 1997^**^ | 25 | TD | CO | 0.10 | 1.00 | L/min | | No
Weiss 1995 | 15 | TD | CO | 0.23 | 2.19 | L/min | stable patients | Yes
| 13 | TD | CO | 0.03 | 2.33 | L/min | unstable patients | Yes
Woltjer 1996a | 37 | TD | SV | −2.70 | 14.65 | ml | | No
Woltjer 1997 | 24 | TD | SV | 0.10 | 11.40 | ml | | No
Wong KL 1996 | 18 | TD | CO | −0.66 | 0.915 | L/min | | Yes
Yakimets 1995 Tr1 | 17 | Fick | CI | −0.56 | 0.78 | L/min.m^2 | at rest | No
| 17 | Fick | CI | −0.75 | 1.12 | L/min.m^2 | at exercise | No
| 17 | Fick | CO | −1.05 | 1.53 | L/min | at rest | No
| 17 | Fick | CO | −1.51 | 2.24 | L/min | at exercise | No
| 17 | Fick | SV | −13.5 | 20.9 | ml | at rest | No
| 17 | Fick | SV | −16.7 | 24.3 | ml | at exercise | No
Yakimets 1995 Tr2 | 28 | TD | CI | −0.18 | 0.70 | L/min.m^2 | immed after surgery | No
| 28 | TD | CI | −1.40 | 0.67 | L/min.m^2 | 2–4 hrs post-op | No
| 28 | TD | CO | −0.43 | 1.33 | L/min | immed after surgery | No
| 28 | TD | CO | −0.36 | 1.24 | L/min | 2–4 hrs post-op | No
| 28 | TD | SV | −3.19 | 13.97 | ml | immed after surgery | No
| 28 | TD | SV | −3.69 | 12.49 | ml | 2–4 hrs post-op | No
Young 1993 | 19 | TD | CI | 1.69 | 1.24 | L/min.m^2 | | Yes
Zacek 1999 | 28 | TD | CI | −0.07 | 1.11 | L/min.m^2 | | Yes

* Aggregated data was with replication, but data at each time point was without replication.

** Bias and SD were estimated from the plot (not reported in the text)

Fourteen studies correctly (single measurement or average of multiple measurements per patient) reported cardiac output for a comparison between TEB and TD among inpatients using the Bland and Altman method. Table 3.4 shows the bias, limits of agreement (+/− 2 standard deviations of the difference), and measurement conditions (another indicator of the quality of measurement) for the eight studies. Individual study results may be interpreted as follows: About 95% of patients would be expected to have the cardiac metric measured by bioimpedance (i.e. cardiac output) within ±2 standard deviations (i.e. the limits of agreement) of the bias. A good test should have a bias as close to zero as possible. Bias near zero and clinically acceptable limits of agreement would imply a favorable comparison of TEB to the alternative. For example, the bias of one study was 0.10, with limits of agreement of −1.90 to 2.10 L/min (van der Meer, deVries, Schreuder, 1997). This suggests that 95% of patients would be expected to have bioimpedance derived cardiac output measurements between −1.90 lower to 2.10 L/min higher than the results derived from TD. This finding would be most useful when the clinical implications of an interval this wide could be assessed.

Table 3.4 Bias and limits of agreement in studies comparing test agreement between TEB (Sramek-Bernstein equation) And TD cardiac output (L/Min) in inpatients

Study | N | Bias | Limits of Agreement | | Measurement Conditions | Measurement Procedure
Study | N | Bias | Lower | Upper | Measurement Conditions | TD | TEB
Balestra 1992 | 30 | 1.99 | −2.41 | 6.39 | external electrodes | M:1 | M:1
Critchley 2000 | 24 | −1.49 | −5.65 | 2.67 | | A set of “nested reading” = mean [3 TDs] + mean [3 TEBs]. Mult. nests per patient
Jewkes 1991 | 16 | 0.86 | −0.88 | 2.60 | | M:3, V<10%, aver taken | M:3, aver taken
Ng 1993 | 27 | −1.40 | −4.2 | 1.4 | | M:3, aver taken | Not clear. One measure used. “Poor quality” signals were excluded.
Sageman 1993 | 50 | 0.33 | −3.07 | 3.73 | | M:3~5, V<15%, aver taken | M:5, aver taken
Van der Meer 1996 | 21 | 0.15 | −1.77 | 2.07 | | M:4, V<15%, aver taken | M:6, V<15%, aver taken
Van der Meer 1997^*^ | 25 | 0.10 | −1.90 | 2.10 | | Multiple, V<15%, assume aver taken | Multiple, V<15%, assume aver taken
Yakimets 1995 Tr2 | 28^**^ | −0.43 | −3.09 | 2.23 | immed after surgery | Not clear | Not clear
Yakimets 1995 Tr2 | 28^**^ | −0.36 | −2.84 | 2.12 | 2–4 hrs post-op | Not clear | Not clear
Random-effects model combined estimate | 191 | 0.006 | −2.87 | 2.89
Random-effects model combined estimate

* Bias and SD were estimated from the plot (not reported in the text)

** Same patients. Biases in the two conditions were averaged and the mean was taken for meta-analysis.

The combined bias and the combined limits of agreement of the bias for cardiac output in the 8 studies were 0.006 and −2.87 to 2.89. If these results were not heterogeneous, the implication would be that 95 percent of inpatients might be expected to have TEB cardiac output limits of agreement of −2.87 to 2.89. The test of heterogeneity across studies was statistically significant, however, for both bias and limits of agreement. This suggests that there may be patient populations where TEB measurements can be much further from the TD measurements than the combined limits of agreement indicate.

Table 3.5 shows that the combined bias and the combined limits of agreement of the bias for stroke volume in these studies were −1.86 and −28.30 to 24.74, respectively. While the test of heterogeneity for the combined limits of agreement was not statistically significant (p=0.59), the test for the bias was.

Table 3.5 Bias and limits of agreement in studies comparing test agreement between TEB (Sramek-Bernstein equation) and TD stroke volume (ml) in inpatients

Study | N | Bias | Limits of Agreement | | Measurement Conditions
Study | N | Bias | Lower | Upper | Measurement Conditions
Jewkes 1991 | 16 | 13.00 | −9.2 | 35.20
Ng 1993 | 27 | −14.00 | −40.8 | 12.80
Yakimets 1995 Tr2 | 28^*^ | −3.19 | −31.13 | 24.81 | immed after surgery
| 28^*^ | −3.69 | −28.67 | 21.29 | 2–4 hrs post-op
Woltjer 1996 | 37 | −2.70 | −32.0 | 26.60
Random-effects model combined estimate | 108 | −1.86 | −28.30 | 24.74
Random-effects model combined estimate

* Same patients. Biases in the two conditions were averaged and the mean was taken for meta-analysis.

### 3.1.6 Training Needs

For the time frame reviewed, no studies were identified that adequately addressed this issue. One study, however, (Belardinelli, Ciompini, Costantini et al., 1996) stated in its Discussion section that it examined the ‘reproducibility’ of TEB by 2 independent and experienced cardiologists on TEB measurements on patients in sinus rhythm with CAD and a previous myocardial infarct either at rest or during exercise on 2 tests separated by 1 week. The authors state that the coefficient of variation was similar for the 2 observers and for the 2 tests; but the results were not presented clearly.

## 3. 2 Indication 2: bioimpedance use for the differentiation of cardiogenic from pulmonary causes of acute dyspnea

### 3.2.1 Patient Management and Health Outcomes

Acute dyspnea has a variety of causes, including cardiogenic and pulmonary causes. Patient management is determined by diagnosis of the underlying cause. No studies, however, were found that evaluated the clinical impact on patient management and/or improved health outcomes from the use of TEB monitoring for differentiation of cardiogenic from pulmonary causes of acute dyspnea (but see also Conclusions section).

### 3.2.2-3.2.6 Other Issues

No studies were found that addressed the following issues regarding this indication:

- TEB performance compared to alternative diagnostic tests for monitoring cardiac output, cardiac index, stroke volume, or other physiologic parameters
- factors that may affect test performance
- potential limitations regarding test performance setting
- factors regarding training.

## 3.3 Indication 3: Applicability of bioimpedance in the optimization of atrioventricular interval for patients with AV sequential cardiac pacemakers

### 3.3.1 Patient Management and Health Outcomes

Some researchers have suggested that finding the optimal atrioventricular (AV) delay is important in maximizing cardiac output in patients with AV sequential pacemakers. We found no well-designed studies for this indication that provide information on the clinical impact on patient management or improved health outcomes after treatments that would be useful in addressing the issues of TEB applicability that have been published to date. Some preliminary studies have been published that measure ranges of values and reproducibility of TEB measurements in patients with pacemakers; these offer some insight into the potential uses of TEB.

Five studies evaluated various aspects of applicability of impedance cardiography-derived cardiac measurements in patients with pacemakers (Haennel, Logan, Dunne, et al., 1998; Ovsyshcher, Gross, Blumberg, et al., 1992; Ovsyshcher, Gross, Blumberg, et al., 1993; Ovsyshcher, Zimlichman, Katz, et al., 1993: Kindermann, Frohlig, Doerr et al. 1997). Two similar studies by the same authors found a mean coefficient of variation of 4% during dual chamber pacing and 6% when the ventricular pacing mode was used to calculate cardiac indices (cardiac and stroke index) from serial (consecutive and non-consecutive) impedance measurements suggesting a high level of reproducibility of the technique at rest during sinus rhythm (Ovsyshcher, Gross, Blumberg, et al., 1992; Ovsyshcher, Gross, Blumberg, et al., 1993). Another study by the same authors evaluated the use of impedance cardiography to optimize pacing (AV) delay in 11 patients (8 with complete heart block and 3 with sick sinus syndrome) with DDD pacemakers or during VVI pacing (3% and 6% respectively) (Ovsyshcher, Zimlichman, Katz, et al., 1993). The authors defined the best programmed AV delay as the setting that produced the highest cardiac index, but they did not validate this measurement with an alternative technique or with data on health outcomes. They found that the correlation coefficient between two consecutive measurements of the cardiac index was 0.94 (p<.0001) in the DDD mode and 0.82 (p<0.0001) in the VVI mode and concluded that “hemodynamic measurements obtained with impedance cardiography can facilitate optimal programming of pacemaker variables.”

Haennel and colleagues used impedance cardiographic monitoring in 10 pacemaker-dependent patients to assess the effects of three different exercise sensing modes on the cardiovascular response to graded exercise (Haennel, Logan, Dunne, et al., 1998). While the study was not designed to assess the accuracy of TEB in this context, the authors stated that “…impedance cardiography provides a simple and reliable means of obtaining repeated hemodynamic data during upright exercise that allows for sequential measurements during a single exercise bout and permits a beat-to-beat examination of the relative contribution of both stroke volume and overall heart rate to cardiac output…”

Kindermann, Frohlig, Doerr et al. (1997) performed a prospective study in 53 patients with high degree AV block to evaluate a new method for the determination of the optimal AV delay using pulsed Doppler echocardiography. These investigators correlated the optimal AV delay using serial TEB determinations of the cardiac index after different settings of AV delay with the optimal delay estimated in the same set of patients. They found a moderate but significant correlation of the AV delay determined with the two methods. It is important to note that in this study TEB-determination of the optimal AV delays of pacemakers was considered the standard and it was compared to an alternative technique. This study did not report health outcomes in two groups of patients in which AV delay optimization was performed using different methods so it is unknown which method of setting the delay is optimal.

Some of the above evidence suggests that TEB is potentially useful in patients with pacemakers and one of these studies compares TEB with an alternative method for optimization of the AV delay setting. None of the studies reported health outcomes after adjustment of the AV delay, so the evidence is insufficient to conclude whether TEB optimization of the AV delay improves health outcomes.

### 3.3.2-3.3.6 Other Issues

No studies were found that addressed the following issues regarding this indication:

- TEB performance compared to alternative diagnostic tests for monitoring cardiac output, cardiac index, stroke volume, or other physiologic parameters
- Factors that may affect test performance
- potential limitations regarding test performance setting
- factors regarding training.

## 3. 4 Indication 4: Bioimpedance use in patients with need of determination for intravenous inotropic therapy

### 3.4.1 Health Outcomes and Patient Management

Non-invasive serial hemodynamic measurements of cardiac parameters might be useful to monitor the effects of parenteral inotropic agents such as dobutamine or milrinone. No studies, however, were found evaluating the clinical impact on patient management and/or improved health outcomes from the use of TEB monitoring of patients in need of inotropic therapy (but see Conclusions section).

### 3.4.2-3.4.6 Other Issues

No studies were found that addressed the following issues regarding this indication

- TEB performance compared to alternative diagnostic tests for monitoring cardiac output, cardiac index, stroke volume, or other physiologic parameters
- factors that may affect test performance
- potential limitations regarding test performance setting
- factors regarding training.

## 3.5 Indication 5: Bioimpedance use in early identification of rejection in post heart transplant myocardial biopsy patients

### 3.5.1 Patient Management and Health Outcomes

The current standard of care for patients with heart transplant includes a regularly scheduled series of cardiac biopsies. Some researchers have suggested that a non-invasive monitoring technique could potentially supplement cardiac biopsies in the early identification of transplant rejection. Weinhold Reichenspurner, and Fulle et al. (1993) assessed the usefulness of TEB in early diagnosis of rejection in 35 heart transplant recipients during the immediate postoperative period and during the outpatient follow-up. These investigators used TEB to measure the stroke volume index, ejection fraction and the acceleration index. They found that average value of the acceleration index during 17 rejection episodes was significantly lower when compared with the non-rejection average. They also found that in their study the diagnostic sensitivity and specificity of the acceleration index for rejection in these patients was 71% and 100% respectively. The authors concluded that TEB is ideal for use "in the outpatient setting to supplement myocardial biopsies.”

This study did not provide data on the clinical impact on patient management or improved health outcomes after treatment. These preliminary findings might be useful if replicated. The fact that we found no other report published on this indication since this study was published almost 10 years ago suggests that the approach has not been widely adopted.

### 3.5.2-3.5.6 Other Issues

No studies were found that addressed the following issues regarding this indication:

- TEB performance compared to alternative diagnostic tests for monitoring cardiac output, cardiac index, stroke volume, or other physiologic parameters
- factors that may affect test performance
- potential limitations regarding test performance setting
- factors regarding training.

## 3.6 Indication 6: Bioimpedance use in cardiac patients with a need for fluid management

### 3.6.1 Patient Management and Health Outcomes

This indication might include monitoring and diagnosis of pulmonary edema or peri-operative monitoring of patients following various types of surgery. Several studies employing a similar technology --- whole body impedance—were found that assessed congestive heart failure patients with need for fluid management; however, we found no study of TEB for this indication.

### 3.6.2-3.6.6 Other Issues

No studies were found that addressed the following issues regarding this indication.

- TEB performance compared to alternative diagnostic tests for monitoring cardiac output, cardiac index, stroke volume, or other physiologic parameters
- Factors that may affect test performance
- Potential limitations regarding test performance setting
- Factors regarding training.

## 3.7 Indication 7: Bioimpedance use in the management of hypertension

### 3.7.1 Patient Management and Health Outcomes

TEB has been used to monitor the efficacy of antihypertensive medications. One study compared TEB-based drug selection to physician management without the support of TEB. Taler, Textor, Augustine, et al. (2002) described a controlled trial involving 104 resistant hypertension patients without a secondary cause or who were to be treated medically. Patients were randomized to hemodynamic-based drug selection or hypertension-specialist-directed drug selection. TEB was used to calculate stroke volume, cardiac output, systemic vascular resistance index, and markers of cardiopulmonary volume. The authors reported that patients with chronic hypertension who were treated using a treatment algorithm and serial hemodynamic measurements obtained by TEB had a small but statistically significant greater decrease in blood pressure compared to patients treated with clinical judgment alone.

Certain methodological weaknesses of this study should be noted. The details of the randomization method are not reported, and it is unclear whether or not all patients were blinded to the use of TEB in their care. There was a small difference in average blood pressure between the “specialist care” and “hemodynamic” monitoring group (4/4 mm Hg difference); this difference was similar in magnitude to the difference between the groups at the end of the study (8/7 mm Hg difference). The blood pressure control rate achieved by the hemodynamic treatment group (56%) was significantly higher than the control rate achieved for the specialist care group (33%). Also, the authors noted that significantly more frequent changes in medications and dosages were made in the hemodynamic group as compared to the specialist care group, while it is unclear how many opportunities for such a change were offered in each study arm. The authors commented that the specialist care group was comprised of nationally certified hypertension specialists with special expertise in the treatment of resistant hypertension, and suggested that monitoring with TEB would have a greater benefit when the alternative was management with a community physician. However, it is also possible that the small improvement in the hemodynamic monitoring group was due to the increased number of specialist visits. It is, therefore, not known what the benefit of TEB would be in community practice with treatment decisions made by generalists.

### 3.7.1 Other Issues

No studies were found that addressed the following issues regarding the following situations:

- TEB performance compared to alternative diagnostic tests for monitoring cardiac output, cardiac index, stroke volume, or other physiologic parameters.
- Factors that may affect test performance.
- Factors regarding training.

The study by Taler, Textor, Augustine, et al. (2002) described above has a serious limitation regarding test performance setting. As noted above, the specialists in the study were national experts, and the results might not be generalizable to a community setting.

## 3.8 Additional Material Regarding Some Of The Indications

While not among the original questions, peer review comments and discussions with AHRQ suggested further analyses.

### 3.8.1 Year of Publication

First, it is of interest to examine whether year of publication affected the results. Advances in technology such as new signal processing algorithms may lead to increased accuracy of bioimpedance over time. Figure 3.3 shows correlation coefficients arrayed by year; no trend toward higher correlation in more recent years is apparent in these graphs. In order to quantitatively estimate whether there has been an improvement in correlation in recent years, we compared an estimate of correlation in the period 1991–1996 to the period 1997 and later. There were twelve studies (305 patients) using cardiac output in the period 1991–1996 comparing TEB among inpatients to TD. The combined correlation coefficient for this group was 0.756 (95% CI: 0.639–0.838), with significant heterogeneity. For the five studies (91 patients) published in 1997 and later, the combined r = 0.487 (95% CI: .299-.640), without significant heterogeneity. The magnitude of the combined correlation coefficient from earlier studies was somewhat higher than that of the coefficient from more recently published studies.

Figure 3.3 Chronological array of correlation coefficients for cardiac output in the inpatient setting chronologically arrayed (TEB vs. TD for Sramek-Bernstein)

Figure 3.3: Chronological array of correlation coefficients for cardiac output in the inpatient setting chronologically arrayed (TEB vs. TD for Sramek-Bernstein)

### 3.8.2 Quality

There were a sufficient number of studies using the Sramek-Bernstein equation involving a comparison of TEB and TD to conduct a meta-analysis comparing one dimension of quality of measurement --- that relating to appropriate analysis of number of measurement replications. There were five studies (148 patients) using cardiac output with a quality grade of “A” with combined r=0.612 (95% CI: 0.422–0.751). There were four studies (88 patients) with a quality grade of “B” with combined r=0.691 (95% CI: 0.333–0.874). There were eight studies (160 patients) with a quality grade of “C” with combined r=0.738 (95% CI: 0.545–0.856). These results, for which there was not significant heterogeneity, do not suggest that this definition of quality is related to the size of the correlation coefficient. Table 3.6 displays quality grades by study.

Table 3.6 Summary of quality of measurements for studies comparing TEB cardiac output and/or cardiac input to TD among inpatients

Study | Reference standard | Test | Setting | Equation | Manufacturer | TD measures | TEB measures | Analysis of correlation | Bias reported? | Quality
Balestra 1992 | TD | CO | IN | SB | NCCOM-4 | M:1 | M:1 | Correlate single measure | Yes | B
Barry 1997 | TD | CO | IN | SB | NCCOM-3 | Multiple | Multiple | Correlate multiple measures | Yes | C
Clancy 1991 | TD | CO | IN | SB | NCCOM-7 | M:3 | M:3 | Correlate multiple measures | Yes | C
Critchley 1996 | TD | CO | IN | SB | NCCOM-7 | A set of “nested reading” = mean [3 TDs] + mean [3 TEBs]. Mult. nests per patient. | | Correlate multiple “nests” | Yes^*^ | C+
Critchley 2000 | TD | CO | IN | SB | NCCOM-7 | M:3, aver taken | M:3, aver taken | Correlate means | Yes | A−
Demeter 1993 | TD | CO | IN | K | Minnesota 304B | M:5, discard high & low values, mean [M:3] taken | M:3, aver taken | Correlate means | No | A
Doering 1995 | TD | CI CO | IN | ND | NCCOM-3 | M:3, V<10%, aver taken | M:3, corresp. measures, aver taken | Correlate means | Yes | A
Drazner 2002 | TD | CI CO | IN | ND | BioZ | M: 3~5, V<10%, assume aver taken | Multiple, aver taken | Correlate means | Yes | A
Genoni 1998 | TD | CO | IN | SB | NCCOM-7 | M:3, V<10% | M:5, discard 2 extreme values | Correlate multiple measures | Yes | C+
Jewkes 1991 | TD | CO | IN | SB | NCCOM-3 | M:3, V<10%, aver taken | M:3, aver taken | Correlate means | Yes | A
Ng 1993 | TD | CO | IN | SB | NCCOM-7 | M:3, aver taken | Not clear. One measure used. “Poor quality” signals were excluded. | Correlate mean [TDs] with TEB | Yes | B
Perrino 1994 | TD | CO | IN | SB | NCCOM-7 | M:3/epoch, V<15%, aver taken/epoch, 6 epoch/patient | Corresp. measures | Claim mean [TDs/epoch] was used. In plot, mult. measures were used. | Yes | C
Pickett 1992 | TD | CO | IN | K | HDC | M:4~5, V<20%, both mult measures and aver were used | Corresp. measures | Correlate both mult. measures and means, separately | Yes | A
Raaijmakers 1998a | TD | CO | IN | SB | ND | M:5, aver taken | Not clear. Mean was used. | Not sure why 32 measures in 13 patients. | Yes | B
Sageman 1993 | TD | CO | IN | SB | NCCOM-7 | M:3~5, V<15%, aver taken | M:5, aver taken | Correlate means | Yes | A
Sageman 2002 | TD | CI | IN | ND | BioZ | Multiple | Multiple | Correlate mult. measures | Yes | C
Spiess 2001 | TD | CI | IN | ND | BioZ | M: 3, V<10%, aver taken | Multiple, aver taken | Correlate means^**^ | Yes | B
Thangathurai 1997 | TD | CO | IN | ND | IQ 101 | Multiple | Multiple | Correlate mult. measures | Yes | C
Van der Meer 1996 | TD | CO | IN | SB | IPG-104 | M:4, V<15%, aver taken | M:6, V<15%, aver taken | Correlate means | Yes | A
Van der Meer 1997 | TD | CO | IN | SB | IPG-104 | Multiple, V<15%, assume aver taken | Multiple, V<15%, assume aver taken | Assume correlate means | Yes | A−
Weiss 1995 | TD | CO | IN | SB | NCCOM-7 | Multiple | Multiple | Correlate multiple measures | Yes | C
Wong KL 1996 | TD | CO | IN | SB | NCCOM-7 | 7~8 pairs of TD & TEB measures per patient | | Correlate multiple measures | Yes | C
Woo 1992 | TD | CO | IN | SB | NCCOM-3 | TD&TEB- M:3, aver taken. “A set” = a pair of mean [TDs] and mean [TEB]. 1~2 sets per patient. | | Correlate multiple mean values | No | C+
Yakimets 1995 Tr2 | TD | CI CO | IN | SB | NCCOM-7 | Not clear | Not clear | Correlate sing measure / aver mult measures | Yes | B
Young 1993 | TD | CI | IN | SB | NCCOM-6 | Multiple | Multiple | Correlate multiple measures | Yes | C
Zacek 1999 | TD | CI | IN | SB | HotmanAH-HHC | M: 4, V<10% | Corresp. measures | Correlate multiple measures | Yes | C
Zubarev 1999 | TD | CO | IN | mod K | BPCS | Multiple | Multiple | Correlate multiple measures | No | C

* Log values were used for estimation of bias

** The aggregated correlation coefficient for the 4 conditions was using multiple measurements per patient, but that for each condition was correlating means. The aggregated correlation coefficient was dropped, and the average correlation coefficient of the 4 conditions was used in the meta-analyses of correlation coefficients.

## 3.9 Summary of Results

Despite the large amount of observational data generated on TEB, almost all of the studies did not use a design that would allow for meaningful comparisons of patient outcomes of care and thus provide evidence to address the questions. In several of these reports the authors anecdotally stated in their discussion sections that they found the method to be clinically useful and helpful for managing patients under various critical circumstances (or the opposite); however, these inferences were not based on randomized or other comparative designs where a group of patients was monitored by TEB and contrasted with a control group. The authors’ conclusions are included in the evidence table.