# METHODS

## 2.1 Assessment Approach

AHRQ, CMS, and T-NEMC staff jointly developed an analytic framework for the assessment of TEB (Figures 2.1 – 2.3). TEB may be used in three different ways: diagnosis, guiding interventions, and monitoring. An example of the diagnostic application of TEB is the differentiation of cardiogenic from pulmonary causes of dyspnea. Examples of guiding interventions and monitoring are monitoring patients’ status in the critical care setting and early diagnosis of rejection in post-heart transplant patients.

Figure 2.1 Analytic Framework- Electrical Bioimpedance for Diagnosis

For diagnostic testing, the sensitivity and specificity of bioimpedance to measure cardiac output or other physiological parameter compared to reference methods will be reviewed (link B). Any direct adverse events of testing mentioned in the studies will be noted. The effects of false positives and false negatives on morbidity/mortality will be reviewed if mentioned in the studies (link D). Any studies that directly demonstrate a change in patient management or a reduction in morbidity/mortality will be reviewed (link A). It is outside the scope of this technology assessment to include other diagnostic strategies except when compared with bioimpedance in clinical studies.

Figure 2.1: Analytic Framework - Electarical Bioimapedance for Diagnosis

Figure 2.2 Analytic Framework-Electrical Bioimpedance for Guiding Interventions

For use in guiding interventions, the sensitivity and specificty of bioimpedance for measuring cardiac output or other physiological parameters compared to reference methods will be reviewed (link B). Any direct adverse effects cited in the studies will be noted (link D). Studies that directly link a change in patient strategy or a reduction in morbidity/mortality to the use of bioimpedance for guiding interventions will be reviewed (link A). It is outside the scope of this technology assessment to review other intervention guidance strategies except to review these strategies when compared to bioimpedance in clinical studies.

Figure 2.2: Analytic Framework - Electrical Bioimpendance for Guiding Interventions

Figure 2.3 Analytic Framework- Electrical Bioimpedance for Monitoring

For monitoring, the correlation of bioimpedance to reference methods will be reviewed (link B). Any direct adverse effects of bioimpedance monitoring cited in the studies will be noted (link D). Any studies that directly demonstrate a change in patient management or a reduction in morbidity/mortality will be reviewed (link A). It is outside the scope of this technology assessment to review other monitoring strategies except when compared to bioimpedance in clinical studies.

Figure 2.3: Analytic Framework - Electrical Bioimpedance for Monitoring

As shown in the analytic framework, the primary purpose of this technology assessment is to find evidence directly demonstrating that the use of TEB leads to changes in patient management that in turn lead to better health outcomes for patients. Adverse effects of TEB and any information about alternative technologies that are directly compared to TEB in clinical trials are also included in the technology assessment. The technology assessment also includes studies of the correlation of TEB with other diagnostic tests such as thermodilution (TD), but most of these studies do not report whether changes in patient management were made, or provide information on health outcomes.

The report on “Recommendations for Evaluating Effectiveness; Executive Committee Working Group Medicare Coverage Policy” (Executive Committee Working Group, 2001) stated that:

“…Few studies have directly measured the effects of a diagnostic or screening test on health outcomes (studies of occult blood testing for colon cancer represent one such exception). Typical studies that evaluate the effectiveness of diagnostic, screening, or monitoring tests focus either on technical characteristics (e.g., does a new radiographic test produce higher resolution images?) or effects on accuracy (does it distinguish between patients with and without a disease better than another test?)…” These points apply to TEB. Few well-designed studies evaluate the impact of this test on clinical outcomes.

Our assessment approach therefore relied on three components and was driven largely by the study design and measurements reported in the literature. The assessments we were able to perform included:

- Assessment of the correlation between TEB and other techniques (high correlation implies that measurements using one method move in the same direction --- upwards or downwards ---as measurements derived from the method being compared)
- Assessment of the bias and limits of agreement of TEB compared to other techniques (tests may have high correlation coefficients while still having systematic differences from the reference test or large random variation for individual measurements; bias and the limits of agreement are one way to measure these variations)
- Qualitative assessment of studies on the use of bioimpedance in clinical situations. Our analyses of these studies are presented in narrative form.

## 2.2 Literature Search

Using the OVID search engine on January 9, 2002, we conducted a broad search of Medline^®^ & PreMedline^®^ (Table 2.1). Filters and limitations were used to eliminate inappropriate publications. The search yielded 8330 citations. The search was conducted for the period from 1966 through January, 2002. The search strategy was restricted to English language publications about human subjects and consisted of the terms impedance, bioimpedance, cardiography, impedance cardiography, electrical impedance. Synonyms for bioimpedance include: electrical bioimpedance, thoracic electrical bioimpedance (TEB), bioelectrical impedance, electrical impedance tomography, bioimpedance spectroscopy, single or multifrequency bioimpedance, and impedance cardiography. Technical experts were consulted, and references in published meta-analysis and selected review articles were examined to identify additional articles. An updated search performed on July 22, 2002 yielded 213 additional abstracts which were identified and screened. Three additional studies qualified and were included in this report.

Table 2.1 Bioimpedance literature search strategy using OVID to search MEDLINE and PREMEDLINE databases on January 2002

Citations | | #
1 | bioimpedance.mp. [mp=ti, ab, rw, sh] | 633
2 | impedance.mp. [mp=ti, ab, rw, sh] | 10735
3 | exp cardiography, impedance/ | 1042
4 | exp electric impedance/ | 3114
5 | exp thermodilution/ | 1495
6 | teb.tw. | 109
7 | 1 or 2 or 3 or 4 or 5 or 6 | 13977
8 | limit 7 to human [Limit not valid in: Pre-MEDLINE; records were retained] | 10434
9 | limit 8 to english language | 8846
10 | Case Report/ | 1031559
11 | 9 not 10 | 8597
12 | limit 11 to (addresses or bibliography or biography or comment or dictionary or directory or editorial or festschrift or interview or lectures or legal cases or letter or news or periodical index) | 267
13 | 11 not 12 | 8330
14 | exp hypertension/ | 152540
15 | hypertens$.tw. | 159472
16 | high blood pressure.tw. | 4698
17 | 14 or 15 or 16 | 204979
18 | 13 and 17 | 330
19 | 13 not 18 | 8000

## 2.3 Selection Criteria

All abstracts were reviewed to identify full articles that met the criteria. Those articles reporting on the methodology of TEB as a diagnostic and/or monitoring tool, or TEB in comparison to another diagnostic technique (such as TD, dye dilution, direct or indirect Fick methods, echocardiographic techniques, or radionuclide angiography) in the following seven clinical situations were retrieved: cardiovascular disease, dyspnea, pacemakers, intravenous inotropic therapy, heart transplant, fluid management, hypertension. Both studies that explicitly compared bioimpedance to other techniques (comparative studies) and studies using other types of assessment (noncomparative, qualitative studies) were included. (See ‘Assessment Of Methodological Issues’ below). After discussions with CMS, studies were excluded if they involved: animals, pediatric or obstetric populations, healthy volunteers, patients on dialysis, patients with acromegaly, cystic fibrosis, AIDS, Crohn’s disease, obesity solely to determine body composition, patients subjected to laparoscopic cholecystectomy, and patients with cirrhosis of the liver who were on fluid management. In addition, related technologies such as electrical impedance tomography (EIT) were excluded. If the article did not specifically say that thoracic impedance was measured, or if non-thoracic electrode placement was used (i.e. whole body impedance), the studies were rejected. Subsequent discussions with CMS further narrowed the inclusion criteria from the initial indication of “cardiac patients with a need for fluid management” to only CHF patients with such a need.

Approximately 275 full articles were retrieved and examined, including five meta-analyses (De Maria and Raisinghani, 2000; Fuller, 1992; Handelsman, 1992; Raaijmakers, Faes, Scholten, et al., 1999; Critchley and Critchley, 2000); one of these was a Technology Assessment report by AHCPR that included studies through part of 1992. All titles in bibliographies of these articles were also reviewed and retrieved, if pertinent. In addition, several lists of articles compiled by CardioDynamics sent to CMS were reviewed.

Because so few articles were obtained for certain conditions, we included articles containing studies with a minimum of 5 subjects for the evaluation of diagnostic test performance or for studies that report correlation with important physiologic parameters.

At the request of CMS, our analyses include only articles published from 1991 onward. This ensures coverage of articles published late in 1991 since the earlier review by AHCPR covered articles prior to that time (Handelsman, 1992). Seventy-seven articles are included in the evidence tables.

Abstracts not published as full articles were not reported in the Results section, were not included in the evidence tables, and were not included in any meta-analyses. In the section entitled “Further Consideration Of Certain Material” some abstracts and allusions to future research were discussed.

## 2.4 Data Extraction

We noted the following elements for each study: primary purpose of the study, clinical situation, reference standard in the comparison tests, design of study, characteristics of the population including setting and funding source, demographics and extended description of the patients enrolled in the study, inclusion and exclusion criteria, description of the equipment and methods of TEB including model and year, manufacturer, calibration and details of the test, placement of leads and procedure followed, quality of the data, method of data analysis, and results. The opinions and conclusions of the authors were quoted where appropriate. Furthermore, the following questions were posed:

- Is the diagnostic test performance compared with a reference standard?
- Does the TEB measurement correlate with clinical measurements?
- Do the authors of the study conclude that TEB is useful, accurate, reliable?
- Are there data to suggest that TEB improves patients' outcomes or affects clinical management?
- Do the authors conclude that TEB improves patients' outcomes or affects clinical management?
- Does this paper discuss the training and experience of the operator? If so, what…
- Does this paper address any problems encountered in operating the device? If so, what…

## 2.5 Assessment of Methodological Issues

The studies were classified into two groups. Comparative studies explicitly compared TEB to another technique. Non-comparative studies examined a relevant aspect of TEB as a diagnostic technique but did not provide data comparing TEB to an alternate technique. For the non-comparative studies, the outcomes and results were described in narrative form.

Four criteria that specifically related to the scope of this report were used to assess major methodological issues regarding the articles included. These criteria pertained to the subject studied (i.e. medical or surgical condition of patients enrolled and inclusion/exclusion criteria) and the apparatus used (manufacturer of the device and specific equation used to calculate cardiac parameters from measured impedance variables). For both types (i.e. comparative and non-comparative) of studies, four yes or no questions were developed and applied. These four questions were:

1. Does the study provide a description of the device that was used to measure TEB (including manufacturer and model)?
2. Does the study describe the equation used to calculate impedance measurements? (researchers using an off-the-shelf clinical system might not know the equations used)
3. Does the study include a description of the patients in the study, with inclusion and exclusion criteria?
4. Does the study include a description of the indication for the use of TEB in the patients enrolled?

The results of this classification are presented in the final column of each evidence table (see below). The criteria were neither used as inclusion criteria nor to provide a detailed assessment of the methodological quality, but rather describe a minimum set of methodological standards that should be applied to the included reports. For studies that measured cardiac output and used TD as the comparison, we added an additional quality measure: the number and appropriate analysis of measurement replications. This is important because researchers have measured variation of 10–20% in repeat TD measurements (Handelsman, 1992); therefore measurement replication is essential to obtain an accurate measurement. We graded each study (A, B, C, where A was highest) according to the methodology employed for obtaining the TD and TEB measurements:

A. At least three TD measurements were made (Stetz, Miller, Kelly, et. al. 1982), with variability between the TD measures less than 20% (by discarding those poor measurements, or excluding those patients with poor measurements from the analysis). Means of the TD and TEB measurements were used in the analysis.
B. Taking only single measurements for both TD and TEB, (or some other data collection problem), but not inappropriately analyzing the results, as in “C” below.
C. Inappropriately treating multiple measurements taken on one patient as if they were “independent” in the statistical analysis.

Both of the above grading approaches focus on key aspects of the measurement process that could be readily inferred from the Methods sections of the articles.

## 2.6 Evidence Tables

The detailed information extracted from the articles along with assessment of methodological issues are included in two evidence tables. Because the types of information extracted from the comparative and non-comparative studies differ in some respects, Evidence Table 1 contains comparative studies, and Evidence Table 2 contains non-comparative studies.

## 2.7 Meta-analysis Methods

Under certain circumstances, an overall estimate of key results is desirable, because such an estimate is more precise than any individual finding. Meta-analysis provides a means of obtaining such an estimate of the results through systematic statistical procedures. While this approach has benefits, it is important to exercise interpretive caution when combining highly variable data, and to consider other information in addition to the quantitative results.

Our meta-analytic framework identified key measures, comparison techniques, and subgroups. Figures 3.1 and 3.2 show the number of studies for each comparison technique as well as the analytic approach, which resulted in the following meta-analyses when there were three or more studies within a subgroup:

Figure 3.1 Analytic framework for correlation meta-analysis

Equation abbreviations: SB= Sramek-Bernstein; K=Kubicek

Notes:

Gray shading indicates studies excluded from meta-analysis.

Studies may not sum to total due to analysis of more than one cardiac metric per study

Figure 3.1: Analytic framework for correlation meta-analysis

Figure 3.2 Analytic framework for meta-analyses of bias and limits of agreement

Equation abbreviations: SB= Sramek-Bernstein; K=Kubicek

Notes:

Gray shading indicates studies excluded from meta-analysis.

Studies may not sum to total due to analysis of more than one cardiac metric per study.

Figure 3.2: Analytic framework for meta-analyses of bias and limits of agreement

- Measures of cardiac function: cardiac output, cardiac index, stroke volume
- Comparison techniques: TD
- Subgroups: setting (inpatient, outpatient, emergency department), study year (1991–1996 vs. 1997–2002), and ‘quality’

While many studies were excluded from the meta-analyses, they were reviewed for relevant qualitative material which was, when appropriate, included in the narrative sections. Following is a summary of the article selection and analysis process:

Step 1 | Step 2 | Step 3 | Step 4
Number of Articles Identified by Literature Searches | Number of Articles Included After Title & Abstract Screening | Number of Articles Included After Full-Text Screening | Final Number of Articles Included in Meta-analyses
Initial search: 8330 Updated search: 213 | TEB articles: 271 Review articles: 5 | Non-comparative studies: 17^*^ | Correlation Coefficients: 22^‡^
Initial search: 8330 Updated search: 213 | TEB articles: 271 Review articles: 5 | Correlation Coefficients: 49^†^ | Correlation Coefficients: 22^‡^
Initial search: 8330 Updated search: 213 | TEB articles: 271 Review articles: 5 | Bias: 36^†^ | Bias: 9^‡^
Total: 8543 | 276 | 77^†^ | 22^†,*^

† There is some overlap between correlation studies and bias studies.

‡ Some articles provide more than one comparison (study); therefore the sums of the studies in the analytic frameworks (Figures 3.1 and 3.2) are larger then the number of articles included in the meta-analyses.

* Non-comparative studies were not in meta-analyses.

Random effects model meta-analyses were performed on studies that compared TEB against alternative methods for the measurement of cardiac function. These studies provided the correlation coefficient and/or the average bias for TEB vs. other techniques, but several analytic issues arose regarding potential duplication of information. To address these issues, the following rules were developed and applied:

1. Whenever a study provided not only data for the whole sample but also for subgroups of patients, only the one entry from the entire sample was used to avoid double counting. Similarly, when a study provided information about the same patients for different conditions (e.g. at rest vs. active) as well as aggregated, only the aggregated data were used. If aggregated data were not provided, the data were averaged across conditions. Averaging such results made the analysis of these studies more comparable to other studies that did not perform subgroup analyses. This avoided over-weighting but, of course, some information was lost.
2. When the study protocol specified repeated measurements on each patient, we replaced the number of paired measurements with the number of patients in the correlation meta-analyses to provide the appropriate weighting.
3. The equations used by the TEB device may impact the results (See below). We therefore only used meta-analysis on groups of studies using the same equation. Because of the number of studies threshold we applied, meta-analyses could only be done with studies that used the Sramek-Bernstein equation.

The software used to conduct the correlation meta-analyses was Comprehensive Meta-analysis Version 1.0.23 (www.Meta-Analysis.com). The bias analyses were done using a web site calculator (http://department.obg.cuhk.edu.hk/ResearchSupport/MetaEffectSize.asp) verified against a standard random effects model formula (Sutton, Abrams, Jones et al., 2000) programmed into a spreadsheet.

## 2.8 Statistical Analysis

The most commonly reported statistic was the correlation between the various cardiac function metrics as measured by TEB vs. the same metrics measured by the various comparison techniques. For example, cardiac output as measured by TD was frequently compared by a correlation coefficient to cardiac output as measured by TEB. Correlation coefficients were therefore an important component of the meta-analysis, despite their limitations. These limitations include:

- the dependence of the correlation on the distribution of true cardiac output levels in the study sample
- the fact that even when the correlation coefficient is close to one, there can be large systematic differences or random variations in individual measurements. (Bland and Altman, 1986).

For correlation coefficients, formal tests for the presence of heterogeneity (gross variation in the size of the correlation coefficients) across studies were performed. The combined estimates of the correlation coefficients and their confidence intervals were derived from random-effects models. These models incorporated both “within” and “between” study variability into the calculations, which generally increases the variability of the combined estimates and produces wider, more conservative confidence intervals and fewer statistically significant findings.

Correlation coefficients measure the correlation of one diagnostic test to another, but do not provide any information about the clinical utility of the diagnostic test. There is no straightforward method of translating the magnitude of correlation coefficients into a statement that reflects the clinical impact of TEB on a population. While such comparisons cannot be translated into clinical impact, it is possible to compare correlations across diagnostic studies to provide a context for interpreting them (De Maria and Raisinghani, 2000). In a later section of this report, we provide some comparative data to provide this context.

The method of Bland and Altman (1986) is commonly used to measure the bias (systematic error) and limits of agreement (random variation) in comparison studies of diagnostic tests. One researcher has pointed out that there is a “…notable lack of consistency in how results of bias and precision statistics are presented…” in studies of methods of measuring cardiac parameters (Critchley, 1999). This, combined with incorrect collection of TD data as reported by some authors (see Results), limits the number of studies for which the bias can be analyzed, but we analyzed bias data where feasible. Finally, we reported bias as (TEB minus comparison) to ensure that the ‘sign’ of the bias was consistent.

## 2.9 Meta-analysis Displays

The meta-analysis displays show:

- Abbreviated name of the effect/metric being analyzed (e.g. CO for cardiac output)
- Article citation (author and year)
- Number of patients used in the comparison
- Graphic description of the individual effects and 95% confidence intervals
- Measurement conditions applying to the comparisons (see Evidence Table 1 for detail)
- Combined random effects model estimate and its confidence bounds