# INTRODUCTION

Indicators of cardiac function, measured through invasive techniques such as pulmonary artery catheters, are often used for applications such as peri-operative monitoring of surgical patients. Thoracic electrical bioimpedance (TEB) cardiography is a noninvasive technology for cardiac output monitoring. TEB has been suggested as a replacement for invasive techniques in critically ill and surgical patients; due to the noninvasive nature of TEB, other applications have also been suggested in the outpatient setting. These applications include optimizing hemodynamic parameters in patients with congestive heart failure, patients with pacemakers, patients needing fluid management, and patients with other conditions.

TEB devices measure a variety of hemodynamic parameters, including

- Cardiac output --- the volume of blood pumped each minute by the heart (Tate, Seeley, Stephens, et al., 1994). Cardiac output is a function of the heart rate (pulse) and the stroke volume (amount of blood pumped by each ventricle of the heart in one contraction).
- Cardiac index --- although this measure is not widely used in practice, it is theoretically more useful than cardiac output, because it adjusts for patient weight and height.
- Ejection fraction --- this important indicator of cardiac function denotes the proportion of total blood in the ventricle pumped out of the heart in one contraction.

A variety of methods and devices have been developed to measure these parameters, and some of these are more invasive than others. Invasive techniques such as cardiac catheterization subject the patient to increased risk, are more complex and costly, and require more training. Another disadvantage of invasive techniques is that they are impractical in the outpatient setting (De Maria and Raisinghani, 2000). Non-invasive techniques that decrease risk but which provide the same or greater accuracy would be of great benefit.

The following table briefly describes several invasive and non-invasive measurement techniques. The techniques are ranked roughly in order of their usefulness as reference standards for the current analysis. (An asterisk indicates that the material is extracted from De Maria and Raisinghani (2000):

| Technique | Invasive? | Description
1. | Direct Fick* | Yes | - Estimates cardiac output through direct measurement of mixed venous blood oxygen concentrations; - Gold standard but usually confined to the cardiac catheterization lab and research settings
2. | Indirect Fick* | Yes | - Similar to direct Fick but uses pulse oximetry assessment of arterial oxygen content
3. | Thermodilution* | Yes | - Estimates cardiac output by measuring change in temperature of a solution injected into the right atrial chamber; - Large measurement variability; - Most widely used in clinical practice
4. | Dye dilution | Yes | - Similar to thermodilution. Dye is injected into pulmonary artery and its concentration is measured at a peripheral site
5. | Radionuclide angiography or ventriculography | Yes | - Estimates cardiac output by dynamic sampling of left ventricular radioactive counts.
6. | Echocardiogram/Doppler | No | - Measures stroke volume and provides a complementary estimation of systolic function by providing velocity values as well as two-dimensional images
7. | Echocardiogram/non-Doppler* | No | - Measures ejection fraction (and therefore stroke volume) by using two-dimensional images of the left ventricle to estimate its volume; - Under-estimates left ventricular volume

TEB is one of a variety of methods used to measure cardiac output, cardiac index, stroke volume, and ejection fraction. TEB takes advantage of the fact that resistance to electrical current in the thorax (the area between the neck and abdomen) varies in relation to the amount of blood in the aorta. It works by introducing a low voltage alternating current between sets of electrodes (leads) placed on the skin surface over the thorax. The difference between the voltage that is introduced by the device and that which the device senses moving through the thorax indicates the amount of resistance (impedance) that the electrical current encounters. The impedance, in conjunction with electrocardiographic results and an equation, are used to estimate stroke volume, from which other cardiac measures may be computed (De Maria and Raisinghani, 2000). Cardiac index is another cardiac parameter that can be calculated from bioimpedance measurements. While ejection fraction can also be calculated, TEB has not been viewed as a substitute for echocardiography or radionuclide ventriculography.

## 1.1 Requests by the Centers for Medicare and Medicaid Services

The Centers for Medicare & Medicaid Services (CMS) requested a technology assessment by the Agency for Health Care Research and Quality (AHRQ) to address a number of issues regarding the value of TEB.

### These issues include

1. A review of the diagnostic test performance of electrical bioimpedance for measurement of cardiac output, stroke volume, thoracic fluid content, and other physiological parameters including the following elements:
  - Comparison to the diagnostic test performance of alternative tests
  - A review of information from clinical trials (if any) on any factors (for example, placement of leads, experience of the operator, comorbid conditions) that may affect the test performance of electrical bioimpedance and the limitations that these factors would place on clinical utility.
2. A review of the clinical trial literature on the use of electrical bioimpedance for the following seven indications, with a focus on data demonstrating changes in patient management and/or improved health outcomes from the use of the device. The first six indications are taken from CMS’ existing national coverage policy on the use of TEB:
  - Noninvasive diagnosis or monitoring of hemodynamics in patients with suspected or known cardiovascular disease.
  - Differentiation of cardiogenic from pulmonary causes of acute dyspnea.
  - Optimization of atrioventricular interval for patients with A/V sequential cardiac pacemakers.
  - Patients with need of determination for intravenous inotropic therapy.
  - Early identification of rejection in post heart transplant myocardial biopsy patients.
  - Cardiac patients with a need for fluid management (Excluding patients on dialysis and with cirrhosis of the liver).
  - Management of hypertension.
3. A review of the setting of the clinical trials of bioimpedance (inpatient vs. outpatient) and issues related to generalizability of data from the inpatient to the outpatient setting.
4. A review of any information available in the clinical trials on training of the persons using the devices and any issues related to this training (e.g., must monitoring data be interpreted only by a cardiologist; can nonphysicians collect the data?)

In 1992, the Agency published a technology assessment that examined the accuracy of measuring cardiac functions with TEB using literature published up to 1992 (Handelsman, 1992). The following excerpt from that report summarizes the findings: “…There continues to be lack of persuasive data derived from rigorous clinical trials supporting the use of [T]EB determinations of cardiac output for the clinical management of any subset of patients… Although many investigators have concluded that [T]EB yields satisfactory results…their reliance on correlation coefficients as the main evidence supporting their stance appears to provide necessary but insufficient evidence of clinical utility in either hospital or outpatient settings…”

The present report is a systematic review of studies that have assessed TEB since the 1992 review. Issues in the assessment of a diagnostic technology include test performance in diagnosing disease, test performance relative to alternatives, and clinical impact. Issues in the assessment of individual research studies include the need for clear definitions, appropriate reference standards, and appropriate statistical analyses. In the following section we describe our systematic review methodology.