# Evidence Table Acronyms and Abbreviations

A/V: Atrioventricular
AF: Atrial Fibrillation
ARDS: Acute Respiratory Distress Syndrome
ARF: Acute Respiratory Failure
BBB: Bundle Branch Block
BMI: Body Mass Index
BPCS: Bioimpedance Polyrheocardiographic System
CABG: Coronary Artery Bypass Graft
CAD: Coronary Artery Disease
CCU: Critical Care Unit
CHD: Coronary Heart Disease
CHF: Congestive Heart Failure
CI: Cardiac Index
CO: Cardiac Output
COPD: Chronic Obstructive Pulmonary Disease
CPB: Cardiopulmonary Bypass
CV: Cardiovascular
CVD: Cardiovascular Disease
D: Bias (against gold standard)
ECG: Electrocardiography
ECW: Extracellular Water
ED: Emergency Department
EF: Ejection Fraction
FEV: Forced Expiratory Volume (in 1 second)
FVC: Forced Vital Capacity
HBP: High Blood Pressure
ICU: Intensive Care Unit
IHD: Ischemic Heart Disease
IPD: Individual Patient Data
LV: Left Ventricle
LVEF: Left Ventricular Ejection Fraction
LVET: Left Ventricular Ejection Time
MAP: Mean Arterial Pressure
MI: Myocardial Infarction
MICU: Medical Intensive Care Unit
MVR: Mitral Valvular Regurgitation
ND: No Data
OR: Operating Room
PAC: Pulmonary Artery Catheter
PCWP: Pulmonary Capillary Wedge Pressure
PEEP: Positive End-expiratory Pressure
r: Correlation Coefficient
r^2^: Multivariate Coefficient of Determination
RM: Repeated Measure
RZ: Time between R wave of ECG and dZ/dt
SAH: Subarachnoid Hemorrhage
SD: Standard Deviation
SI: Stroke Index
SM: Single Measurement
STI: Systolic Time Intervals
SV: Stroke Volume
TBW: Total Body Water
TD: Thermodilution
TEB: Thoracic Electrical Bioimpedance
TFI: Thoracic Fluid Index
TLC: Total Lung Capacity
TS: Tricuspid Stenosis
VC: Vital Capacity
VEPT: Volume of Electrically Participating Tissue
WMS: Wall Motion Score
ZEEP: Zero End Respiratory Pressure
Z_o_: Baseline Impedance