# REFERENCES

1 Meyer CG, Penn I, James L. Liver transplantation for cholangiocarcinoma: results in 207 patients. Transplantation. 2000;69:1633-7. [pmid: 10836374].
2 de Groen PC, Gores GJ, LaRusso NF, Gunderson LL, Nagorney DM. Biliary tract cancers. N Engl J Med. 1999;341:1368-78. [pmid: 10536130].
3 Masada CT, Markin RS. Cholangiocarcinoma following orthotopic liver transplantation. A unique pattern of recurrence diagnosed using immunohistochemical stains. J Clin Gastroenterol. 1994;18:155-8. [pmid: 8189012].
4 Loinaz C, Abradelo M, Gomez R, et al. Liver transplantation and incidental primary liver tumors. Transplant Proc. 1998;30:3301-2. [pmid: 9838459].
5 Iwatsuki S, Todo S, Marsh JW, et al. Treatment of hilar cholangiocarcinoma (Klatskin tumors) with hepatic resection or transplantation. J Am Coll Surg. 1998;187:358-64. [pmid: 9783781].
6 Abu-Elmagd KM, Selby R, Iwatsuki S, et al. Cholangiocarcinoma and sclerosing cholangitis: clinical characteristics and effect on survival after liver transplantation. Transplant Proc. 1993;25:1124-5. [pmid: 8382850].
7 Goss JA, Shackleton CR, Farmer DG, et al. Orthotopic liver transplantation for primary sclerosing cholangitis. A 12-year single center experience. Ann Surg. 1997;225:472-81. discussion 481–3. [pmid: 9193175].
8 Pichlmayr R, Weimann A, Klempnauer J, et al. Surgical treatment in proximal bile duct cancer. A single-center experience. Ann Surg. 1996;224:628-38. [pmid: 8916878].
9 Liden H, Norrby J, Friman S, Olausson M. Liver transplantation for primary sclerosing cholangitis--a single- center experience. Transpl Int. 2000;13:S162-4. [pmid: 11111988].
10 Casavilla FA, Marsh JW, Iwatsuki S, et al. Hepatic resection and transplantation for peripheral cholangiocarcinoma. J Am Coll Surg. 1997;185:429-36. [pmid: 9358085].
11 Pichlmayr R, Weimann A, Oldhafer KJ, Schlitt HJ, Tusch G, Raab R. Appraisal of transplantation for malignant tumours of the liver with special reference to early stage hepatocellular carcinoma. Eur J Surg Oncol. 1998;24:60-7. [pmid: 9542520].
12 Flickinger JC, Epstein AH, Iwatsuki S, Carr BI, Starzl TE. Radiation therapy for primary carcinoma of the extrahepatic biliary system. An analysis of 63 cases. Cancer. 1991;68:289-94. [pmid: 2070327].
13 Klempnauer J, Ridder GJ, Werner M, Weimann A, Pichlmayr R. What constitutes long-term survival after surgery for hilar cholangiocarcinoma?. Cancer. 1997;79:26-34. [pmid: 8988723].
14 Neuhaus P. Combined liver transplantation and pancreatoduodenectomy for irresectable hilar bile duct carcinoma. Br J Surg. 1996;83:422. [pmid: 8665214].
15 Figueras J, Llado L, Valls C, et al. Changing strategies in diagnosis and management of hilar cholangiocarcinoma. Liver Transpl. 2000;6:786-94. [pmid: 11084070].
16 Goldstein RM, Stone M, Tillery GW, et al. Is liver transplantation indicated for cholangiocarcinoma?. Am J Surg. 1993;166:768-71. discussion 771–2. [pmid: 8273866].
17 Nashan B, Schlitt HJ, Tusch G, et al. Biliary malignancies in primary sclerosing cholangitis: timing for liver transplantation. Hepatology. 1996;23:1105-11. [pmid: 8621141].
18 Ahrendt SA, Pitt HA, Nakeeb A, et al. Diagnosis and management of cholangiocarcinoma in primary sclerosing cholangitis. J Gastrointest Surg. 1999;3:357-67. discussion 367–8. [pmid: 10482687].
19 Knechtle SJ, D’Alessandro AM, Harms BA, Pirsch JD, Belzer FO, Kalayoglu M. Relationships between sclerosing cholangitis, inflammatory bowel disease, and cancer in patients undergoing liver transplantation. Surgery. 1995;118:615-9. discussion 619–20. [pmid: 7570313].
20 Urego M, Flickinger JC, Carr BI. Radiotherapy and multimodality management of cholangiocarcinoma. Int J Radiat Oncol Biol Phys. 1999;44:121-6. [pmid: 10219804].
21 Washburn WK, Lewis WD, Jenkins RL. Aggressive surgical resection for cholangiocarcinoma. Arch Surg. 1995;130:270-6. [pmid: 7534059].
22 Gruenberger. Tumor recurrence after oLTX. Transplant. 1996;9(Suppl 1):S151-S154.
23 De Vreede I, Steers JL, Burch PA, et al. Prolonged disease-free survival after orthotopic liver transplantation plus adjuvant chemoirradiation for cholangiocarcinoma. Liver Transpl. 2000;6:309-16. [pmid: 10827231].
24 Alessiani M, Tzakis A, Todo S, Demetris AJ, Fung JJ, Starzl TE. Assessment of five-year experience with abdominal organ cluster transplantation. J Am Coll Surg. 1995;180:1-9. [pmid: 8000645].
25 Neuhaus P, Jonas S, Bechstein WO, et al. Extended resections for hilar cholangiocarcinoma. Ann Surg. 1999;230:808-18. discussion 819. [pmid: 10615936].
26 Neuhaus P, Jonas S. Surgery for hilar cholangiocarcinoma--the German experience. J Hepatobiliary Pancreat Surg. 2000;7:142-7. [pmid: 10982606].
27 Mieles L, Todo S, Tzakis A, Starzl TE. Treatment of upper abdominal malignancies with organ cluster procedures. Clin Transplant. 1990;4:63-7. [pmid: 10147561].
28 Foo ML, Gunderson LL, Bender CE, Buskirk SJ. External radiation therapy and transcatheter iridium in the treatment of extrahepatic bile duct carcinoma. Int J Radiat Oncol Biol Phys. 1997;39:929-35. [pmid: 9369143].
29 Knechtle SJ, Kalayoglu M, D’Alessandro AM, et al. Should abdominal cluster transplantation be abandoned?. Transplant Proc. 1993;25:1361-3. [pmid: 8442141].
30 Madariaga JR, Iwatsuki S, Starzl TE, Todo S, Selby R, Zetti G. Hepatic resection for cystic lesions of the liver. Ann Surg. 1993;218:610-4. [pmid: 8239774].
31 Madariaga JR, Iwatsuki S, Todo S, Lee RG, Irish W, Starzl TE. Liver resection for hilar and peripheral cholangiocarcinomas: a study of 62 cases. Ann Surg. 1998;227:70-9. [pmid: 9445113].
32 Gores GJ. Liver transplantation for malignant disease. Gastroenterol Clin North Am. 1993;22:285-99. [pmid: 8389734].
33 Gores GJ. Early detection and treatment of cholangiocarcinoma. Liver Transpl. 2000;6:S30-4. [pmid: 11084082].
34 Cherqui D, Tantawi B, Alon R, et al. Intrahepatic cholangiocarcinoma. Results of aggressive surgical management. Arch Surg. 1995;130:1073-8. [pmid: 7575119].
35 Neuhaus P, Blumhardt G. Extended bile duct resection--a new oncological approach to the treatment of central bile duct carcinomas? Description of method and early results. Langenbecks Arch Chir. 1994;379:123-8. [pmid: 8196428].
36 Proye C. Natural History of Liver Metastasis of Gastroenteropancreatic Neuroendocrine Tumors: Place for Chemoembolization. World J Surg. 2001;25:685-688. [pmid: 11376397].
37 Que FG, Nagorney DM, Batts KP, Linz LJ, Kvols LK. Hepatic resection for metastatic neuroendocrine carcinomas. American Journal of Surgery. 1995;169:36-42. discussion 42–3. [pmid: 7817996].
38 Ihse I, Perrson B, Tibblin S. Neuroendocrine metastases of the liver. World J Surg. 1995;1995:76-82. [pmid: 7740814].
39 Todo S, Tzakis A, Abu-Elmagd K, et al. Abdominal multivisceral transplantation. Transplantation. 1995;59:234-40. [pmid: 7530873].
40 Lang H, Oldhafer KJ, Weimann A, et al. Liver transplantation for metastatic neuroendocrine tumors. Ann Surg. 1997;225:347-54. [pmid: 9114792].
41 Le Treut YP, Delpero JR, Dousset B, et al. Results of liver transplantation in the treatment of metastatic neuroendocrine tumors. A 31-case French multicentric report. Ann Surg. 1997;225:355-64. [pmid: 9114793].
42 Routley D, Ramage JK, McPeake J, Tan KC, Williams R. Orthotopic liver transplantation in the treatment of metastatic neuroendocrine tumors of the liver. Liver Transpl Surg. 1995;1:118-21. [pmid: 9346552].
43 Dousset B, Boudet MJ, Soubrane O, Calmus Y, Bernard O, Houssin D. Liver transplantation in patients with preexisting malignancy. Transplant Proc. 1995;27:1793-5. [pmid: 7725508].
44 Frilling A, Rogiers X, Malago M, Liedke O, Kaun M, Broelsch CE. Liver transplantation in patients with liver metastases of neuroendocrine tumors. Transplant Proc. 1998;30:3298-300. [pmid: 9838458].
45 Schweizer RT, Alsina AE, Rosson R, Bartus SA. Liver transplantation for metastatic neuroendocrine tumors. Transplant Proc. 1993;25:1973. [pmid: 8385828].
46 Ishak KG, Sesterhann IA, Goodman MZD. Epitheloid hemangioendothelioma of the liver: A clinicopathologic and follow-up study of 32 cases. Hum Pathol. 1984;15:839-852. [pmid: 6088383].
47 Madariaga JR, Marino IR, Karavias DD, et al. Long-term results after liver transplantation for primary hepatic epithelioid hemangioendothelioma. Ann Surg Oncol. 1995;2:483-7. [pmid: 8591077].
48 Makhlouf HR, Ishak KG, Goodman ZD. Epithelioid hemangioendothelioma of the liver: a clinicopathologic study of 137 cases. Cancer. 1999;85:562-82. [pmid: 10091730].
49 Hung CF, Jeng LB, Lee WC, Lin DY, Tan PP, Chen MF. Liver transplantation for epithelioid hemangioendothelioma. Transplant Proc. 1998;30:3307-9. [pmid: 9838462].
50 Ben-Haim M, Roayaie S, Ye MQ, et al. Hepatic epithelioid hemangioendothelioma: resection or transplantation, which and when?. Liver Transpl Surg. 1999;5:526-31. [pmid: 10545542].
51 Jaques DP, Coit DG, Casper ES, Brennan MF. Hepatic metastases from soft-tissue sarcoma. Ann Surg. 1995;221:392-397. [pmid: 7726675].
52 Rojter S, Villamil FG, Petrovic LM, et al. Malignant vascular tumors of the liver presenting as liver failure and portal hypertension. Liver Transpl Surg. 1995;1:156-61. [pmid: 9346558].
53 Olthoff KM, Millis JM, Rosove MH, Goldstein LI, Ramming KP, Busuttil RW. Is liver transplantation justified for the treatment of hepatic malignancies?. Arch Surg. 1990;125:1261-6. discussion 1266–8. [pmid: 2171452].
54 Zibari GB, Riche A, Zizzi HC, et al. Surgical and nonsurgical management of primary and metastatic liver tumors. Am Surg. 1998;64:211-20. discussion 220–1. [pmid: 9520809].
55 Ismail T, Angrisani L, Gunson BK, et al. Primary hepatic malignancy: the role of liver transplantation. Br J Surg. 1990;77:983-7. [pmid: 2169946].
56 Moreno-Gonzalez E, Loinaz C, Gomez R, et al. Orthotopic liver transplantation in primary liver tumors. J Surg Oncol Suppl. 1993;3:74-7. [pmid: 8389177].
57 Kavolius J, Fong Y, Blumgart LH. Surgical resection of metastatic liver tumors. Surgical Oncology Clinics of North America. 1996;5:337-52. [pmid: 9019355].
58 McCarter MD, Fong Y. Metastatic liver tumors. Seminars in Surgical Oncology. 2000;19:177-88. [pmid: 11126381].
59 Farmer DG, Shaked A, Colonna JO 2nd, et al. Radical resection combined with liver transplantation for foregut tumors. Am Surg. 1993;59:806-12. [pmid: 8256933].
60 Oldhafer KJ, Lang H, Schlitt HJ, et al. Long-term experience after ex situ liver surgery. Surgery. 2000;127:520-7. [pmid: 10819060].
61 Penn I. Posttransplantation de novo tumors in liver allograft recipients. Liver Transpl Surg. 1996;2:52-9. [pmid: 9346628].
62 Petrassi A, Rossi M, Venettoni S, Alfani D, Roncone A, Cortesini R. Multivisceral cluster transplantation: a preliminary experience. Chir Ital. 1999;51:79-86. [pmid: 10514921].
63 Penn I. Evaluation of the candidate with a previous malignancy. Liver Transpl Surg. 1996;2:109-13. [pmid: 9346710].
64 Boring CC, Squires TS, Tong T, Montgomery S. Cancer Statistics, 1994. Cancer J Clin. 1994;44:7.
65 Piehler JM, Crichlow RW. Primary carcinoma of the gallbladder. Surg Gynecol Obstet. 1978;147:929. [pmid: 362580].
66 Bartlett DL. Gallbladder cancer. Seminars in Surgical Oncology. 2000;19:145-55. [pmid: 11126379].
67 von Schonfeld J, Lange R, Bug R, Erhard J. Liver transplantation in a 29-year-old patient with gallbladder carcinoma complicating primary sclerosing cholangitis. Z Gastroenterol. 1998;36:977-81. [pmid: 9880824].
68 Washburn WK, Lewis WD, Jenkins RL. Liver transplantation with incidental gallbladder carcinoma in the recipient hepatectomy. HPB Surg. 1994;8:147-9. [pmid: 7880774].
69 Saigal S, Norris S, Srinivasan P, et al. Successful outcome of orthotopic liver transplantation in patients with preexisting malignant states. Liver Transpl. 2001;7:11-5. [pmid: 11150415].
70 Carithers RL Jr. Liver transplantation. American Association for the Study of Liver Diseases. Liver Transpl. 2000;6:122-35. [pmid: 10648593].
71 Marks DI, Dousset B, Robson A, et al. Orthotopic liver transplantation for hepatic GVHD following allogeneic BMT for chronic myeloid leukaemia. Bone Marrow Transplant. 1992;10:463-6. [pmid: 1464011].
72 Rosen CB, Nagorney DM. Cholangiocarcinoma complicating primary sclerosing cholangitis. Semin Liver Dis. 1991;11:26-30. [pmid: 1646485].
73 Nimer SD, Milewicz AL, Champlin RE, Busuttil RW. Successful treatment of hepatic venoocclusive disease in a bone marrow transplant patient with orthotopic liver transplantation. Transplantation. 1990;49:819-21. [pmid: 2326879].
74 Rapoport AP, Doyle HR, Starzl T, Rowe JM, Doeblin T, DiPersio JF. Orthotopic liver transplantation for life-threatening veno-occlusive disease of the liver after allogeneic bone marrow transplant. Bone Marrow Transplant. 1991;8:421-4. [pmid: 1768978].
75 Chiche L, Dao T, Salame E, et al. Liver adenomatosis: reappraisal, diagnosis, and surgical management: eight new cases and review of the literature. Ann Surg. 2000;231:74-81. [pmid: 10636105].
76 Blakolmer K, Gaulard P, Mannhalter C, et al. Unusual peripheral T cell lymphoma presenting as acute liver failure and reappearing in the liver allograft. Transplantation. 2000;70:1802-5. [pmid: 11152113].
77 Adams J, Lodge JP, Parker D. Liver transplantation for metastatic hemangiopericytoma associated with hypoglycemia. Transplantation. 1999;67:488-9. [pmid: 10030302].
78 Balsells J, Margarit C, Murio E, et al. Adenocarcinoma in Caroli’s disease treated by liver transplantation. HPB Surg. 1993;7:81-6. discussion 86–7. [pmid: 8260439].
79 Shaked A, Colonna JO, Goldstein L, Busuttil RW. The interrelation between sclerosing cholangitis and ulcerative colitis in patients undergoing liver transplantation. Ann Surg. 1992;215:598-603. discussion 604–5. [pmid: 1632681].
80 Saldeen K, Friman S, Olausson M, Olsson R. Follow-up after liver transplantation for primary sclerosing cholangitis: effects on survival, quality of life, and colitis. Scand J Gastroenterol. 1999;34:535-40. [pmid: 10423073].
81 Soderdahl G, Duraj F, Wahlberg J, Groth C, Ericzon BG. Hepatic malignancies, a controversial indication for liver replacement: 10 year experience from a Scandinavian center. Transplant Proc. 1995;27:3495-6. [pmid: 8540066].
82 Calne RY. Resection of large liver tumours: lessons from transplantation surgery. Lancet. 1993;342:386. [pmid: 8101898].
83 Sansalone CV, Colella G, Caccamo L, et al. Orthotopic liver transplantation for primary biliary tumors: Milan multicenter experience. Transplant Proc. 1994;26:3561-3. [pmid: 7998275].
84 Haug CE, Jenkins RL, Rohrer RJ, et al. Liver transplantation for primary hepatic cancer. Transplantation. 1992;53:376-82. [pmid: 1310823].
85 Chung SW, Greig PD, Cattral MS, et al. Evaluation of liver transplantation for high-risk indications. Br J Surg. 1997;84:189-95. [pmid: 9052430].
86 Graziadei IW, Wiesner RH, Marotta PJ, et al. Long-term results of patients undergoing liver transplantation for primary sclerosing cholangitis. Hepatology. 1999;30:1121-7. [pmid: 10534330].
87 Robles R, Parrilla P, Bueno FS, et al. Liver transplantation in the management of Klatskin’s tumor. Transplant Proc. 1999;31:2494-5. [pmid: 10500686].
88 Launois B, Terblanche J, Lakehal M, et al. Proximal bile duct cancer: high resectability rate and 5-year survival. Ann Surg. 1999;230:266-75. [pmid: 10450742].
89 Miros M, Kerlin P, Walker N, Harper J, Lynch S, Strong R. Predicting cholangiocarcinoma in patients with primary sclerosing cholangitis before transplantation. Gut. 1991;32:1369-73. [pmid: 1661259].
90 Strasser S, Sheil AG, Gallagher ND, Waugh R, McCaughan GW. Liver transplantation for primary sclerosing cholangitis versus primary biliary cirrhosis: a comparison of complications and outcome. J Gastroenterol Hepatol. 1993;8:238-43. [pmid: 8518394].
91 Berdah SV, Delpero JR, Garcia S, Hardwigsen J, Le Treut YP. A western surgical experience of peripheral cholangiocarcinoma. Br J Surg. 1996;83:1517-21. [pmid: 9014664].
92 Cherqui D, Alon R, Piedbois P, et al. Combined liver transplantation and pancreatoduodenectomy for irresectable hilar bile duct carcinoma. Br J Surg. 1995;82:397-8. [pmid: 7796023].
93 Muiesan P, Shanmugam RP, Devlin J, et al. Orthotopic liver transplantation for primary sclerosing cholangitis. Transplant Proc. 1994;26:3574-6. [pmid: 7998278].
94 Farges O, Malassagne B, Sebagh M, Bismuth H. Primary sclerosing cholangitis: liver transplantation or biliary surgery. Surgery. 1995;117:146-55. [pmid: 7846618].
95 Pichlmayr R, Lamesch P, Weimann A, Tusch G, Ringe B. Surgical treatment of cholangiocellular carcinoma. World J Surg. 1995;19:83-8. [pmid: 7740815].
96 Alsina AE, Bartus S, Hull D, Rosson R, Schweizer RT. Liver transplant for metastatic neuroendocrine tumor. J Clin Gastroenterol. 1990;12:533-7. [pmid: 1699994].
97 Anthuber M, Jauch KW, Briegel J, Groh J, Schildberg FW. Results of liver transplantation for gastroenteropancreatic tumor metastases. World J Surg. 1996;20:73-6. [pmid: 8588417].
98 Bechstein WO, Neuhaus P. Liver transplantation for hepatic metastases of neuroendocrine tumors. Ann N Y Acad Sci. 1994;733:507-14. [pmid: 7978901].
99 Bramley PN, Lodge JP, Losowsky MS, Giles GR. Treatment of metastatic Vipoma by liver transplantation. Clin Transplant. 1990;4:276-8. discussion 279. [pmid: 10150088].
100 Caplin ME, Buscombe JR, Hilson AJ, Jones AL, Watkinson AF, Burroughs AK. Carcinoid tumour. Lancet. 1998;352:799-805. [pmid: 9737302].
101 Claure RE, Drover DD, Haddow GR, Esquivel CO, Angst MS. Orthotopic liver transplantation for carcinoid tumour metastatic to the liver: anesthetic management. Can J Anaesth. 2000;47:334-7. [pmid: 10764178].
102 Coperchini ML, Jones R, Angus P, Read A, Schmidt G, Zalcberg J. Liver transplantation in metastatic carcinoid tumour. Aust N Z J Med. 1996;26:702-4. [pmid: 8958368].
103 Curtiss SI, Mor E, Schwartz ME, et al. A rational approach to the use of hepatic transplantation in the treatment of metastatic neuroendocrine tumors. J Am Coll Surg. 1995;180:184-7. [pmid: 7850052].
104 Dousset B, Houssin D, Soubrane O, Boillot O, Baudin F, Chapuis Y. Metastatic endocrine tumors: is there a place for liver transplantation?. Liver Transpl Surg. 1995;1:111-7. [pmid: 9346551].
105 Dousset B, Saint-Marc O, Pitre J, Soubrane O, Houssin D, Chapuis Y. Metastatic endocrine tumors: medical treatment, surgical resection, or liver transplantation. World J Surg. 1996;20:908-14. discussion 914–5. [pmid: 8678970].
106 Frilling A, Rogiers X, Knofel WT, Broelsch CE. Liver transplantation for metastatic carcinoid tumors. Digestion. 1994;55:104-6. [pmid: 7698531].
107 Frilling A, Rogiers X, Malago M, Liedke OM, Kaun M, Broelsch CE. Treatment of liver metastases in patients with neuroendocrine tumors. Langenbecks Arch Surg. 1998;383:62-70. [pmid: 9627173].
108 Gulanikar AC, Kotylak G, Bitter-Suermann H. Does immunosuppression alter the growth of metastatic liver carcinoid after orthotopic liver transplantation?. Transplant Proc. 1991;23:2197-8. [pmid: 1871841].
109 Hao L, Friedman AL, Navarro VJ, West B, Robert ME. Carcinoid tumor of the common bile duct producing gastrin and serotonin. J Clin Gastroenterol. 1996;23:63-5. [pmid: 8835905].
110 Martin M, Tarara D, Wu YM, et al. Intrahepatic arterial chemoembolization for hepatocellular carcinoma and metastatic neuroendocrine tumors in the era of liver transplantation. Am Surg. 1996;62:724-32. [pmid: 8751763].
111 Socci C, Mazzaferro V, Regalia E, et al. Insulin independence after islet-liver transplantation for metastatic neuroendocrine pancreatic tumor. Transplant Proc. 1994;26:577-8. [pmid: 8171563].
112 Caplin ME, Hodgson HJ, Dhillon AP, et al. Multimodality treatment for gastric carcinoid tumor with liver metastases. Am J Gastroenterol. 1998;93:1945-8. [pmid: 9772061].
113 Loinaz C, Gomez R, Gonzalez-Pinto I, et al. A decade of liver transplantation in primary liver tumors. Transplant Proc. 1998;30:3296-7. [pmid: 9838457].
114 Yokoyama I, Todo S, Iwatsuki S, Starzl TE. Liver transplantation in the treatment of primary liver cancer. Hepatogastroenterology. 1990;37:188-93. [pmid: 2160421].
115 Vaillant JC, Balladur P, Nordlinger B, et al. Repeat liver resection for recurrent colorectal metastases. Br J Surg. 1993;80:340-4. [pmid: 8472146].
116 De Maria N, Colantoni A, Van Thiel DH. Liver transplantation after successful resection of a superficial gastric cancer. Hepatogastroenterology. 1998;45:1842-5. [pmid: 9840160].
117 Rhodes DF, Lee WM, Wingard JR, et al. Orthotopic liver transplantation for graft-versus-host disease following bone marrow transplantation. Gastroenterology. 1990;99:536-8. [pmid: 2365200].
118 Rosen HR, Martin P, Schiller GJ, et al. Orthotopic liver transplantation for bone-marrow transplant-associated veno-occlusive disease and graft-versus-host disease of the liver. Liver Transpl Surg. 1996;2:225-32. [pmid: 9346652].
119 Schlitt HJ, Tischler HJ, Ringe B, et al. Allogeneic liver transplantation for hepatic veno-occlusive disease after bone marrow transplantation--clinical and immunological considerations. Bone Marrow Transplant. 1995;16:473-8. [pmid: 8535323].