# METHODS

## Sources of Evidence

The primary source of evidence for this report was the published literature. In addition, registry data from the United Network for Organ Sharing (UNOS) was used to estimate the frequency with which transplantation has been performed in the United States in patients with underlying malignancies during the past decade.

### Published Literature

The published literature regarding transplantation in the setting of malignancy was identified by performing a search of the MEDLINE® database. The search was restricted to articles published in English between January 1990 and July 2001. The final list of search terms was derived after consultation with hepatologists, oncologists and from terms identified from review articles. Search terms included: neoplasms, tumor$, canc$, carcin$, neoplas$, metasta$, malignan$, liver transplantation, liver transplant$, hepat$ transplant$, cholangiocarcinoma, hemangioendothelioma, hemangiosarcoma, leiomyosarcoma, lymphoma, neuroendocrine, ampudoma, islet cell. The MEDLINE® search was limited to human studies between 1990–2001, for adults aged 19 to 65.

#### Inclusion criteria

Studies were included that described any outcomes following liver transplantation in adult patients (age >18) with primary or metastatic liver tumors (other than hepatocellular carcinoma), or in patients with a history of prior extrahepatic malignancy.

#### Exclusion criteria

Studies were excluded if: they were published in languages other than English, focused exclusively on children (age <18), presented outcomes following liver transplantation that could not be differentiated from outcomes following other types of therapeutic interventions, described transplantation for a non-malignant tumor or premalignant state (eg, biliary papillomatosis), included only patients with concurrent hepatocellular carcinoma, presented outcomes following liver transplantation that were not distinguishable for individual tumors, presented only de novo cancers following liver transplantation, included tumors in the donor or donor graft, reviewed other sources of primary patient data or represented duplicate reports of previously-described patients.

Titles and abstracts were reviewed to identify relevant articles. The bibliographies from review articles and from reports that fulfilled the inclusion criteria were examined to identify other potentially relevant studies. All studies were reviewed in duplicate and consensus was achieved for all reports that were included in this evidence report based upon the inclusion and exclusion criteria described above.

Data extraction included information on the study location, patient characteristics, type of intervention (surgical procedure, neoadjuvant and adjuvant therapies), study duration, and outcomes of interest (patient survival, disease-free survival, graft-survival, quality of life, and comparisons to other therapies). The data-extraction instrument is included in Appendix I. Studies were categorized according to authors and transplant center to identify duplicate reports of the same patients. Duplicate reports were included if they provided additional follow-up data; however patients were counted only once. Emphasis was placed on the largest and most methodologically rigorous studies within each clinical category. Pooled data from studies describing outcomes on 10 or more patients was provided when possible by dividing the total number of patients reaching an endpoint in studies with adequate follow-up by the total number of patients transplanted.

### UNOS Registry

Information was requested from the United Network for Organ Sharing to provide an estimate of the frequency with which liver transplantation has been performed in the setting of malignancy in the United States during the last decade. The United Network of Organ Sharing (UNOS) under contract with the Organ Procurement and Transplantation Network (OPTN) oversees a registry that includes information on almost every cadaveric transplant performed in the United States. Some transplant centers have supplied data following living donor liver transplantation as well. In accordance with OPTN requirements, transplant centers report diagnostic information on patients at the time of listing for transplant, at the time of transplant, and at regular follow-up intervals after transplantation. Data collected include the recipient’s primary liver disease and the presence of known malignancies at the time of listing. However, this database has limitations. It is generally believed that many liver transplant programs have been delinquent in submitting follow-up data. Detailed information on patients with prior non-hepatic malignancies was not available. It was not possible to correlate the patients included in the UNOS registry with those described in the literature. Further information about UNOS or the transplant registry can be found via the Internet at www.unos.org.