# EXECUTIVE SUMMARY

Background Controversy exists over the role of liver transplantation in patients with preexisting malignancies. Of primary concern is the possibility of tumor recurrence, a risk that must be weighed against the scarcity of available organs and the expense of organ transplantation. On the other hand, transplantation may offer the only opportunity for cure of the tumor and/or the underlying liver disease. This technology assessment reviews the available evidence regarding the outcomes of liver transplantation in patients with primary and metastatic liver tumors other than hepatocellular carcinoma (HCC), and patients with preexisting, non-hepatic malignancies.

Methods The primary sources of evidence for this report was the published literature identified by performing a search of the MEDLINE® database. Studies were categorized according to transplant center and author to eliminate duplicate reports. In addition, registry data from the United Network for Organ Sharing (UNOS) was used to estimate the frequency with which transplantation has been performed in the United States in patients with underlying malignancies during the past decade. UNOS, under contract with the Organ Procurement and Transplantation Network (OPTN), oversees a registry that includes information on almost every cadaveric transplant performed in the United States. However, the database is limited due to incomplete reporting of follow-up information.

Results One hundred ten reports met inclusion criteria. Forty-nine transplant centers published results that included a total of 1,011 transplant recipients. The largest experience was with cholangiocarcinoma and neuroendocrine tumors (total 822 patients). Other tumors included hemangioendothelioma as well as a variety of other sarcomas and rare tumors. Only a few reports described the outcomes in patients transplanted for metastatic disease and preexisting extrahepatic malignancy. All studies were individual case reports or case series. Details regarding patient and tumor characteristics, immunosuppression and outcomes of interest (patient, disease-free, and graft survival and quality of life) were reported with variable detail.

The UNOS Registry included 37,357 liver transplants performed in the United States between 1990 and 2001. Of these 889 patients had a malignancy at the time of transplant including 271 in which a malignancy other than HCC was described as the primary reason for transplantation. Despite an increase in the total number of transplants performed annually (from 2,177 in 1990 to 4,384 in 2000), the number of transplants performed for tumors other than HCC declined. In 1990, 52 recipients underwent OLT for non-HCC tumors compared to 13 in 2000. An average of 20 transplants was performed each year for the last five years, while an average of 32 transplants was performed each year from 1990–1995. Of over 200 living donor liver transplants to adult recipients performed in the United States between 1997 and 2001, 9 have been to recipients with non-HCC tumors.

Patients and disease-free survival was generally lower than for transplantation performed for other indications. Nevertheless, long-term survival was described in individual patients with a variety of underlying malignancies. There were insufficient data to make definitive conclusions regarding patient, tumor, or transplant-related characteristics that predicted improved survival, although several were described in individual reports. Only a few reports described the effect of transplantation on quality of life. Most were in patients with neuroendocrine tumors in whom quality-of-life appeared to improve even in those with recurrent tumors.

No studies directly compared liver transplantation to other therapeutic options. As a result, it was not possible to directly compare the outcome of liver transplantation to other potential treatments. However, most patients undergoing transplantation were not considered to be eligible for or had failed other treatments, or were offered transplantation because it was considered to provide the only chance for cure of the tumor. In some cases the tumor was detected incidentally in patients who were undergoing transplantation for end-stage liver disease. The expected survival in such patients is typically less than three months.

Conclusions Liver transplantation for tumors other than HCC is performed uncommonly in the United States reflecting the infrequent occurrence of some of these tumors as well as the recognition that survival in such patients is poor compared to patients transplanted for nonmalignant causes. Nevertheless, long-term survivors continue to be described suggesting that transplantation may be beneficial in individual cases. The available evidence does not provide a clear profile of patients who might be optimal candidates for such therapy.