# BACKGROUND

Orthotopic liver transplantation (in situ replacement of a recipient’s liver with a donor liver) has become the definitive therapy for patients with end stage liver disease due to a variety of causes. However, its role in the treatment of patients with preexisting malignancies is controversial. Included in this group are patients with primary and metastatic liver tumors, and those with a known history of extrahepatic malignancies. A number of studies have suggested that the risk of tumor recurrence (due to residual disease and the effects of immunosuppression) in these patients may be excessive to justify orthotopic liver transplantation (OLT). On the other hand, despite its many potential short and long-term complications, OLT may offer the only chance of cure for some patients while providing meaningful palliation for others.

Few transplant centers currently offer liver transplantation to patients with known hepatic malignancies other than hepatocellular carcinoma. However, a detailed understanding of patients with hepatic malignancies who might be optimal candidates for liver transplantation has become increasingly important. Technological advances are continuing to improve the ability to detect liver tumors in early stages offering the hope that patients with a relatively favorable prognosis can be identified. Furthermore, the growth of living donor transplantation has provided an additional source of organs. Potential living donor may be willing to provide an organ if it would offer a chance of a cure; these organs may otherwise have been unavailable. However, the chance for long-term survival must be sufficient to justify the operative risk of the donor.

Prognosis following transplantation may be influenced by several variables such as specific tumor characteristics, the type of transplant operation (e.g. standard OLT or multivisceral transplantation), and the use of neoadjuvant or adjuvant treatment strategies. The greatest experience has been with hepatocellular carcinoma in which long-term survival has been demonstrated following OLT in carefully selected patients. Neoadjuvant and adjuvant treatment strategies continue to be studied in an attempt to broaden the pool of potential candidates. The Medicare national coverage policy for liver transplantation for cancers was recently expanded to include coverage for hepatocellular carcinoma.

Much less is known regarding the efficacy of liver transplantation in patients with malignancies other than hepatocellular carcinoma. Thus, the primary aim of this report was to assess the available evidence regarding liver transplantation in these settings. Specific outcomes of interest included: patient and disease-free survival, graft survival, the effect on quality-of life, comparison to other available treatments for specific tumors, and comparison with the results of OLT for other indications.