# Data Extraction Instrument

Author: | Journal | Year;Volume:Pages:
Center Name/Locations: | Extractor Name/Date | Page of Extraction:
| Years of transplants reported | Able to distinguish tumor transplant data | | □Yes | □No
Total Number of Patients______ | Characteristics | Outcomes of Interest
□ Cholangiocarcinoma | Age: | Survival Time:
□ PSC____ | Length follow-up: | Operative Mortality | □ Excluded
□ No PSC____ | | | □ Included
□ PSC & No PSC____ | Tumor Size | Patient Survival
□ NOS____ | | 6m | 1y | 3y | 5y
□ GB Cancer____
□ Neuroendocrine____
□ Neuroendocrine____
□ Carcinoid____ | Stage of Disease
□ Islet Cell Tumors____ | | Disease-Free Survival
□ Insulinoma____ | | 6m | 1y | 3y | 5y
□ Gastrinoma____
□ Glucagonoma____ | Histologic Features
□ VIPoma____
□ Other____
□ Hemangiosarcoma____ | | Graft Survival
□ Hemangioendothelioma____ | Known immunosuppression agents? | 6m | 1y | 3y | 5y
□ Sarcoma
□ Metastatic Disease____
Location: | Neo/Adjuvant therapies?
□ Other____ | | Quality of Life
Procedure Reported
□ Liver transplant
□ Liver-pancreas-duodenum | Other comments
□ Other: ____________ | | Other