# Abbreviations and Acronyms

ADL: Activities of daily living
AECOPD: Acute exacerbation of chronic obstructive pulmonary disease
AHRF: Acute hypercapnic respiratory failure
AHRQ: Agency for Healthcare Research and Quality
ALS: Amyotrophic lateral sclerosis
BMI: Body mass index
BPAP: Bi-level positive airway pressure
CI: Confidence interval
cmH2O: Centimeters of water (pressure)
CMS: Centers for Medicare and Medicaid Services
COPD: Chronic obstructive pulmonary disease
CPAP: Continuous positive airway pressure
EPAP: Expiratory positive airway pressure
EPC: Evidence-based Practice Center
ER: Emergency room
FDA: Food and Drug Administration
FEV1: Forced expiratory volume in one second
FFM: Full face mask
FVC: Forced vital capacity
H2O: Water
HMV: Home mechanical ventilators
ICU: Intensive care unit
IPAP: Inspiratory positive airway pressure
IR: Incidence rate
IRR: Incidence rate ratio
Kg: Kilogram
KQ: Key Question
LTACH: Long-term acute care facility
LTOT: Long-term oxygen therapy
m: meters
mbad: megabar
MHRA: Medicines and Healthcare Products Regulatory Agency
MIP: Maximal inspiratory pressure
Mbar: Megabar
mL: Milliliters
mmHg: Millimeters of mercury
NA: Not Available
NIPPV: Non-invasive positive pressure ventilation
NIV: Non-invasive ventilation
NMD: Neuromuscular diseases
NOS: Not otherwise specified
OHS: Obesity hypoventilation syndrome
OR: Odds ratio
PaCO2: Partial pressure of arterial carbon dioxide
PaO2: Partial pressure of arterial oxygen
PCF: Peak cough flow
PEEP: Positive end expiratory pressure
pH: Potential of hydrogen
PICOTS: Population, interventions, comparisons, outcomes, timing, and setting
Pimax: Maximal inspiratory mouth pressures
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PSG: Polysomnogram
PtcCO2/TcCO2: Pressure of transcutaneous carbon dioxide
QoL: Quality of life
RAD: Respiratory assist device
RCT: Randomized controlled trial
S: Spontaneous mode
SaO2: Arterial blood oxygen saturation
SF-36: Medical Outcomes Study Questionnaire Short Form
SMD: Standardized mean difference
SNP: Sniff nasal pressure
SOE: Strength of evidence
ST: Spontaneous/timed breath mode
ST90: Sleep time with oxygen saturation below 90%
TRD: Thoracic restrictive diseases
VAPS: Volume assured pressure support
VC: Vital capacity
WMD: Weighted mean difference