# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: from the Agency for Healthcare Research and Quality our task order officers, Lionel Bañez, M.D. and Elise Berliner, Ph.D., from Centers for Medicare and Medicaid Services Susan M. Miller, M.D and James Rollins, M.D.