# Appendix H Figures

Figure H.1 6 Minute Walk Test-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; WMD: Weighted mean difference

Figure H.2 Activities of Daily Living-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

Figure H.3 Dyspnea-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

Figure H.4 Exacerbation-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial

Figure H.5 ICU admissions-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial

Figure H.6 Need for Intubation-BPAP versus No Device in COPD patients

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

Figure H.7 Mortality-BPAP versus No Device in COPD patients

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

Figure H.8 Quality of Life-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

Figure H.9 Hospital Readmission-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial

Figure H.10 Sleep Quality-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

Figure H.11 Subgroup Analysis: Level of Hypercapnia (PaCO2) used as an Initiation Criterion for Initiation of NIPPV on Mortality-BPAP

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

Figure H.12 Subgroup Analysis: Level of Hypercapnia (PaCO2) used as an Initiation Criterion for Initiation of NIPPV on Hospital Readmission-BPAP versus No Device in COPD patients

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

Figure H.13 Subgroup Analysis: Level of Hypercapnia (PaCO2) used as an Initiation Criterion for Initiation of NIPPV on Quality of Life-BPAP versus No Device in COPD Patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference