# Appendix F Results from the Included Studies

## KQ1 What are the patient characteristics and/or laboratory criteria and/or target level measurable improvements considered for the initiation and continuation of noninvasive positive pressure ventilation supplied by a Home Mechanical Ventilator (HMV), Bilevel Positive Airway Pressure device (BPAP), and Continuous Positive Airway Pressure device (CPAP)?

Table F.1 COPD - New initiation of home device

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Murphy, 2017^46^ RCT | BPAP ST | -COPD (FEV1 < 50%); -NIPPV during hospital admission | -PaCO2 >53 mmHg; -PaO2 <55 mmHg or PaO2 < 60 mmHg with polycythemia, pulmonary hypertension or cor pulmonale; -ST 90<30%; -pH >7.30; (daytime, room air) | “High pressure ventilation strategy” titrated during polysomnography
Oscroft, 2014^50^ RCT | BPAP IVAPS versus BPAP ST | -COPD (FEV1 < 50%); -Mixed stable disease or following AECOPD | -PaCO2 >7 kPa (53 mmHg); -pH >7.35 or PtcCO2 >9 kPa (68 mmHg); (daytime) | BPAP IVAPS: Target minute ventilation and target back up respiratory rates were the mean minute ventilation and rates that the patients had during a one hour trial of pressure support ventilation at 15 cmH2O while awake. The device then attempted to reproduce target minute ventilation overnight by automatically adjusting the inspiratory pressures in the range 7-25 cmH2O. (Titration took on average 3.3 [SD 1.6] days); BPAP ST: IPAP and backup rate were adjusted to optimize ventilation with the aim of reducing PtcCO2. EPAP set at 5cmH20. (Titration took on average 5.2 [SD 2.8] days)
Paone, 2014^51^ Observational | BPAP ST | -COPD (FEV1 < 50%); -NIPPV during hospital admission | -PaCO2 > 50 mmHg (after awakening from a night without NIPPV) | Maximum tolerated IPAP to target tidal volume of 6 mL/kg (measured body weight). EPAP set at 2-8 cmH2O. Backup rate set at 12 breaths/min.
Galli, 2014^29^ Observational | BPAP NOS | -COPD (ICD-9); -NIPPV during hospital admission | -PaCO2 > 45 mmHg
Bhatt, 2013^4^ RCT | BPAP NOS | -COPD (FEV1 NOS); -Stable (no AECOPD in prior 4 weeks) | -PaCO2 <52 mmHg | IPAP set at 15 cmH2O. EPAP set at 5 cmH2O. Initiation performed in home by respiratory therapist over 1 week.
Duiverman^22,^ ^23^, 2011 RCT | BPAP ST | -COPD (FEV1<50%); -Stable (no AECOPD in prior 4 weeks) | -PaCO2 >6.0 kPa (45 mmHg); -pH >7.35; (daytime, room air) | Maximum tolerated IPAP to target PaCO2<6.0 kPa and PaO2 > 8.0 kPa.
Oscroft, 2010^48^ Observational | BPAP ST started in AECOPD | -COPD (FEV1 <50%); -NIPPV during hospital admission for AECOPD | -PaCO2 >7.5 kPa (56 mmHg); -pH 7.35-7.45; (daytime); or; -PaCO2 >6.5 kPa (49 mmHg); -pH 7.35-7.45 + PtcCO2; >9 kPa (68 mmHg); (daytime)
Oscroft, 2010^48^ Observational | BPAP ST started in stable COPD | -COPD (FEV1 <50%); -Stable (no current AECOPD) | -PaCO2 >7.5 kPa (56 mmHg); -pH 7.35-7.45; (daytime); or; -PaCO2 >6.5 kPa (49 mmHg); -pH 7.35-7.45 + PtcCO2 >9 kPa (68 mmHg); (daytime)
Cheung, 2010^12^ RCT | CPAP versus BPAP ST | -NIPPV during hospital admission for AECOPD | -PaCO2 > 6 kPa (45 mmHg); -pH <7.35 | CPAP: CPAP set at 5 cmH2O; BPAP ST: Maximum tolerated IPAP (range 10 to 20 cmH2O) to target tidal volume 7-10 mL/kg. EPAP set at 5 cmH2O. Backup rate set at 14 breaths/min.
Casanova, 2000^10^ RCT | BPAP S | -COPD (FEV1 <45%); -Stable (no AECOPD in prior 3 months) | | Maximum tolerated IPAP (≥8 cmH2O above EPAP) to target 20% decrease in respiratory rate and visible decrease in accessory muscle use and dyspnea. EPAP set at 4 cmH2O. (Titrated in hospital for 1 week).
Garrod, 2000^30^ RCT | BPAP S | -COPD (FEV1 <50%); -Stable (no AECOPD in prior 4 weeks); -exercise intolerance due to dyspnea | | Maximum tolerated IPAP and EPAP. (Titrated over 1 week).
Clini, 1998^15^ Observational | BPAP ST | -COPD (FEV1<50%); -Stable (no AECOPD in prior 4 weeks); -LTOT ≥12 months; -≥1 ICU admission due to AECOPD in prior 2 years | -PaCO2 >6 kPa (45 mmHg); -pH >7.35; -PaO2 <8 kPa (60 mmHg); (daytime, room air, rest) | Minimal IPAP to achieve an expiratory tidal volume > 8ml/kg. EPAP was set in order not to overcome the intrinsic PEEP. Backup rate set at 10 breaths/min.
Clini, 1996^14^ Observational | BPAP ST | -COPD (FEV1 30-49%); -LTOT ≥18 months; -≥1 hospital admission due to AECOPD in prior 18 months | -PaCO2 >6.7 kPa (50 mmHg) | Minimal IPAP to achieve an expiratory tidal volume > 8ml/kg. Rate set at 10 breaths/min (Titration over 15 days in hospital).
Zhou, 2017^70^ RCT | BPAP ST | -COPD (FEV1<50%); -Stable (no AECOPD in prior 4 weeks) | -Hypercapnia (daytime, rest) NOS | Maximum tolerated IPAP (≥ 10 cmH2O). EPAP set at 4 cmH2O. Backup rate set at 16 breaths/min.
Marquez-Martin, 2014^38^ RCT | BPAP ST | -COPD (FEV1<50%); -Stable (no AECOPD in prior 3 months) | -PaCO2 > 45 mmHg; -PaO2 < 60 mmHg | Maximum tolerated IPAP (10-20 cmH2O) to target good clinical response and SaO2. EPAP set at 4 cmH2O. Backup rate set at 12 breaths/min.
Köhnlein, 2014^37^ RCT | BPAP ST | -COPD (FEV1<30%); -Stable (no AECOPD in prior 4 weeks) | -PaCO2 ≥ 7 kPa (53 mmHg); -pH ≥ 7.35; (daytime, rest) | Targeted to reduce baseline PaCO2 by ≥ 20% or achieve PaCO2 <6.5 kPa (49 mmHg).
De Backer, 2011^19^ RCT | BPAP NOS | -COPD (FEV1<50%); -AECOPD requiring hospitalization | -PaCO2 >45 mmHg on day 5-12 of hospitalization | Targeted SaO2 >90% during 90% of time and reduction in PaCO2 ≥ 5% in 1 hour.
Dreher, 2010^21^ RCT | HMV (pressure assist/control) versus HMV (PSV ST) | -COPD (Gold stage IV); -Stable (no current AECOPD). | -PaCO2 >45 mmHg (daytime) and PaCO2 >50 mmHg (nocturnal) | HMV (pressure assist/control): Maximum tolerated IPAP to target maximum reduction in PaCO2 (normocapnia if possible). EPAP set to avoid dynamic hyperinflation (3-6 cmH2O). I:E ratio set at 1:2 and modified per patient tolerance. Inspiratory flow trigger set to 3 l/min.; HMV (PSV ST): IPAP set to 14-16 mbar. Backup rate set to 8 breaths/minute. Inspiratory flow trigger set to 3 l/min. Expiratory trigger set to 70% of maximal inspiratory flow.
McEvoy, 2009^43^ RCT | BPAP S | -COPD (FEV1<50% or <1.5L); -Stable disease; -LTOT for ≥3 months | -PaCO2 >46 mmHg (at least twice in prior 6 months during stability) | Maximum tolerated IPAP-EPAP difference (≥5 cmH2O). EPAP set at 3 cmH2O and titrated up to target reduction of snoring and obstructive hypopneas/apneas in polysomnogram. (Titration performed in elective hospital admission for 3-4 days.)
Tsolaki, 2008^65^ Observational | BPAP ST | -COPD (FEV1 <50%); -Stable (no AECOPD in prior 4 weeks) | -PaCO2>50 mmHg; -PaO2<60 mmHg (room air) | IPAP and EPAP to target patient comfort, decreased accessory muscle use, lower respiratory rate, and decrease in PaCO2 >5% after 1 hour. (Titration in hospital).
Windisch, 2006^69^ Observational | HMV with pressure controlled ventilation (PCV) mode | -COPD NOS; -Stable (no worsening symptoms in prior 2 weeks, respiratory rate <30 breaths/minute, no signs of current respiratory infection, no changes in symptoms or medications in prior 3 months); -NIPPV in hospital admission | -pH≥7.35 | Maximum tolerated IPAP to target a maximum decrease in PaCO2
Gay, 1996^31^ RCT | BPAP ST versus sham CPAP lowest setting | -COPD (FEV1 < 40%); -Stable disease | -PaCO2 > 45 mmHg; (daytime, rest) | IPAP set to 10 cmH2O. EPAP set to lowest possible. Backup rate to target patient comfort.
Gad, 2014^28^ Observational | BPAP ST | -COPD (FEV1 < 50%); -Stable (no AECOPD in prior 4 weeks); PaCO2>50 mmHg | -PaCO2 >50 mmHg; -pH > 7.35; (daytime) | Maximum tolerated IPAP (targeting 15-20 cmH2O). EPAP 3-6 cmH2O. (Titration occurred in hospital over 2-3 day period.)
Sin, 2007^62^ RCT | BPAP NOS versus sham CPAP 4 cmH2O | -COPD (FEV1 NOS); -Stable disease | | Maximum tolerated IPAP (maximum of 20 cmH2O). EPAP set at 4 cmH2O.
Heinemann, 2011^34^ Observational | BPAP (pressure controlled ventilation) | -COPD (FEV1 NOS); -invasive mechanical ventilation for AECOPD, pneumonia, or postoperative respiratory failure; -prolonged weaning from invasive mechanical ventilation | -PaCO2>52.5mmHg; or; -pH<7.35 (recurrent acidosis)
Budweiser, 2007^8^ Observational | BPAP (pressure controlled ventilation) | -COPD (FEV1 <50%); -Stable and unstable disease | -PaCO2>55mmHg; -pH<7.35 (recurrent acidosis) | Maximum tolerated IPAP to achieve maximum reduction in PaCO2.
Clini, 2002^16^ RCT | BPAP ST | -COPD (FEV1 NOS); -Stable (no AECOPD in prior 4 weeks) | -PaCO2 >6.6 kPa (50 mmHg); -pH>7.35; (daytime, room air) | Maximum tolerated IPAP with goal decrease in PaCO2 >5% after 1 hour; and nocturnal SaO2≥90% for 90% of time. (Titration in hospital).
Struik, 2014^64^ RCT | BPAP ST | -COPD (FEV1 <50%); -NIPPV or invasive mechanical ventilation in hospital admission | -PaCO2 >6 kPa (45 mmHg) | Maximum tolerated IPAP to achieve normal PaCO2. Respiratory rate was set to match respiratory rate of patient, I:E set to 1:3 with a short rise time and then titrated on comfort.
Durao, 2018^25^ Observational | HMV/BPAP mix | -COPD (NOS); -AECOPD | | Maximum tolerated IPAP to achieve maximum reduction in PaCO2. Backup raespiratory rate was increased above resting respiratory rate if persistent hypercapnia. Pressure support ventilation was switched to pressure controlled ventilation if persistent hypercapnia. Volume assured pressure assisted/controlled ventilation was used if prolonged ventilation (>12 hours/day) or intolerant to IPAP >25 cmH2O)
Durao, 2018^25^ Observational | HMV/BPAP mix | -COPD (NOS); -Stable (no current AECOPD)
Duiverman, 2017^24^ RCT | HMV /BPAP mix (pressure controlled ventilation versus pressure support ventilation) | -COPD (FEV1 NOS); -Stable (no AECOPD in prior 4 weeks); -≥ 2 AECOPD with acute hypercapnic respiratory failure (pH<7.35) per year | -PaCO2 ≥6.7 kPa (50 mmHg) (daytime); or; -PaCO2 ≥7.3 kPa (55 mmHg) (nighttime); or; -Nighttime rise in PtCO2 ≥1.3 kPa (10 mmHg) | Pressure controlled ventilation: Maximum tolerated IPAP to achieve maximum reduction in PaCO2. Backup rate set just above spontaneous breathing frequency. EPAP set at 4-6cm H2O.; Pressure support ventilation: Maximum tolerated IPAP, with maximum IPAP of 18 cmH2O and maximum backup rate of 14 breaths/minute.
Blankenburg, 2017^5^ Observational | HMV (pressure controlled ventilation or pressure support ventilation) | -COPD (FEV1 NOS); -Stable (no AECOPD in prior 2 weeks) | -PaCO2>7.0kPa (53mmHg); -pH>7.35 | Goal of titration was normal PaCO2 as well as patient tolerability of NIPPV. Titration started in pressure controlled ventilation mode. If pressure controlled ventilation was not achievable, pressure support ventilation was used. Inspiratory pressure was set to relieve “air hunger” on inspiration or to reach a tidal volume ≥800mL. PEEP was increased to maximally tolerated. Respiratory rate was set at 2 breaths/minute above the spontaneous respiratory rate.
Tsolaki, 2011^66^, Observational | BPAP ST | -COPD (FEV1 NOS); -Stable (no AECOPD in prior 4 weeks); -Symptoms of nocturnal hypoventilation (fatigue, dyspnea, morning headaches) | -PaCO2 ≥50mmHg; -pH>7.35 | Patients were hospitalized for 2–3 days during the initial application of NIV, in order to ensure maximal compliance. The modality of NIV was pressure support ventilation delivered by a variable positive airway pressure device (VPAP III ST, ResMed, Sydney, N.S.W., Australia), set in the spontaneous/timed mode with a backup respiratory rate of 8–14 breaths / min. Inspiratory and expiratory positive airway pressures (IPAP and EPAP, respectively) were adjusted according to the patient’s comfort and synchrony with the ventilator and a marked reduction in the use of accessory muscles. For the first 2 h from the initiation of ventilation the patient was observed by a pulmonologist and a fully trained nurse, in order to assure a decrease in accessory respiratory muscle use and respiratory rate, check the patient’s comfort of mask ventilation and possible air leaks of the system. Supplemental oxygen was added as needed in order to maintain oxygen saturation between 88 and 92%. Arterial blood gases were measured 1 h after the initiation of ventilation. A 5% decrease in Pa CO 2 values was considered as adequate ventilatory support.

AECOPD: acute exacerbation of chronic obstructive pulmonary disease, BPAP: Bilevel Positive Airway Pressure, cmH2O: centimeters of water (pressure), COPD; chronic obstructive pulmonary disease, CPAP: Continuous Positive Airway Pressure, EPAP: expiratory positive airway pressure, FEV1: Forced expiratory volume in one second, HMV: Home Mechanical Ventilation, ICU: Intensive Care Unit, IPAP: inspiratory positive airway pressure, IVAPS: intelligent volume assured pressure support, kPa: kilopascal, LTOT: long term oxygen therapy, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive positive pressure Ventilation, NOS: Not otherwise Specified, PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, PEEP: positive end expiratory pressure, pH: potential of hydrogen, PSV: Pressure support ventilation, RCT: randomized controlled trial, S: spontaneous mode, SaO2: arterial blood oxygen saturation, ST: spontaneous/timed breath mode

Table F.2 COPD - Established home device use

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Salturk, 2015^57^ Observational | BPAP ST | -COPD (FEV1 not specified); -post ICU admission; -home NIPPV ≥ 4 hours/day | | IPAP titrated to achieve “desired tidal volume” (maximum 30 mbar)
Hitzl, 2009^35^ Observational | HMV (pressure cycled assist control mode) | -Stable (no current AECOPD); -HMV initiated ≥3 months
Funk, 2010^27^ RCT | BPAP NOS for 6 months | -COPD “standard criteria” NOS; -AECOPD requiring NIPPV or invasive ventilation; -chronic nocturnal NIPPV use at home for ≥ 6 months | -PaCO2 > 45 mmHg (stable, measured immediately after awakening from a night without mechanical ventilation | Maximum tolerated IPAP (10-20 cmH2O). EPAP set to 5 cmH2O. Inspiratory time was limited to a maximum of 1.3 s to avoid leak-induced prolongation of inspiration.
Funk, 2010^27^ RCT | BPAP NOS more than 6 months | -COPD “standard criteria” NOS; -AECOPD requiring NIPPV or invasive ventilation; -chronic nocturnal NIPPV use at home for ≥ 6 months | -PaCO2 > 45 mmHg (stable, measured immediately after awakening from a night without mechanical ventilation | Maximum tolerated IPAP (10-20 cmH2O). EPAP set to 5 cmH2O. Inspiratory time was limited to a maximum of 1.3 s to avoid leak-induced prolongation of inspiration.
Vasquez, 2017^67^ cohort | BPAP NOS versus CPAP NOS versus HMV NOS | -COPD (ICD-9)
Oscroft, 2010^49^ RCT | BPAP ST (pressure controlled ventilation) | -COPD, FEV1<50%, FEV1/FVC<70%, TLC>80%, >20 pack year smoking history; -Stable (no current AECOPD: no increased breathlessness, cough or sputum in the prior 4 weeks, no increase in PaCO2 and no decrease in FEV1 since study initiation); -Chronic nocturnal NIPPV use at home for ≥ 3 months | -pH 7.35-7.45; -PaCO2>7.5 kPa or PtcCo2>9kPa
Oscroft, 2010^49^ RCT | No PAP | | -pH 7.35-7.45; -PaCO2>7.5 kPa or PtcCo2>9kPa

AECOPD: acute exacerbation of chronic obstructive pulmonary disease, BPAP: Bilevel Positive Airway Pressure, cmH2O: centimeters of water (pressure), COPD; chronic obstructive pulmonary disease, EPAP: expiratory positive airway pressure, FEV1: Forced expiratory volume in one second, HMV: Home Mechanical Ventilation, ICU: Intensive Care Unit, IPAP: inspiratory positive airway pressure, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive positive pressure Ventilation, NOS: Not otherwise Specified, RCT: randomized controlled trial, ST: spontaneous/timed breath mode

Table F.3 Thoracic Restrictive Disorders - New initiation of home device

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Salturk, 2015^57^ Observational | BPAP ST | Kyphoscoliosis NOS | | IPAP titrated to achieve “desired tidal volume” (maximum 30 mbar)
Domenéech-Clar, 2003^20^ Observational | BPAP NOS | -Kyphoscoliosis or fibrothorax or thoracoplasty; -Stable (no infection in past 3 months); -Symptoms of hypercapnia (fatigue, dyspnea, morning headache) | -PaCO2 >45 mmHg; or; -FVC <40%; or; -MIP <60 cm H2O; or; -nocturnal SaO2 < 88% for ≥ 5 consecutive minutes | IPAP increased (minimum 10 cmH2O) to target a normal PaCO2 or a decrease of at least 10 mmHg. (Titration occurred in hospital)
Nauffal, 2002^47^ Observational | BPAP NOS | -Kyphoscoliosis NOS; -stable (no infection in past 3 months); -symptoms (fatigue, dyspnea, morning headache) | -PaCO2 >45 mmHg; or; -FVC <50%; or; -MIP <60 cm H2O; or; -SaO2 < 88% for ≥ 5 consecutive minutes by nocturnal oximetry | IPAP and EPAP titrated to maximize change of arterial blood gases. (Titration occurred in hospital)
Masa, 2000^39^ Observational | HMV (volume controlled ventilation with change to pressure controlled ventilation if volume could not be tolerated) | -Kyphoscoliosis (scoliosis angle [Cobb] >90 degrees; -FEV1/FVC ≥65% -Apnea-hypopnea index ≤ 20 events/hour | -PaCO2 >47 mmHg for at least 3 months | Ventilator parameters adjusted to target maximum reduction in PaCO2 as well as patient tolerance, air leakage, and nocturnal saturation >90%. Patient initially treated with volume-cycled ventilator. Patients with poor compliance to volume-cycled ventilator were switched to a bilevel pressure ventilator. (Titration occurred in hospital over 3-7 days)
Schonhofer, 2001^61^ Observational | HMV (volume controlled ventilation with change to BPAP ST if volume could not be tolerated) | -TRD (post-TB or scoliosis NOS); -Stable disease (stable PaCO2, no hospital admission in prior 1 month) | -Absence of severe acidosis; -PaCO2 45-55 mmHg
Tsolaki, 2011^66^ Observational | BPAP ST | -TRD NOS; -Stable (no acute exacerbation in prior 4 weeks); -Symptoms of nocturnal hypoventilation (fatigue, dyspnea, morning headaches) | -PaCO2 ≥45mmHg; -pH>7.35 | Patients were hospitalized for 2–3 days during the initial application of NIV, in order to ensure maximal compliance. The modality of NIV was pressure support ventilation delivered by a variable positive airway pressure device (VPAP III ST, ResMed, Sydney, N.S.W., Australia), set in the spontaneous/timed mode with a backup respiratory rate of 8–14 breaths / min. Inspiratory and expiratory positive airway pressures (IPAP and EPAP, respectively) were adjusted according to the patient’s comfort and synchrony with the ventilator and a marked reduction in the use of accessory muscles. For the first 2 h from the initiation of ventilation the patient was observed by a pulmonologist and a fully trained nurse, in order to assure a decrease in accessory respiratory muscle use and respiratory rate, check the patient’s comfort of mask ventilation and possible air leaks of the system. Supplemental oxygen was added as needed in order to maintain oxygen saturation between 88 and 92%. Arterial blood gases were measured 1 h after the initiation of ventilation. A 5% decrease in Pa CO 2 values was considered as adequate ventilatory support.

BPAP: Bilevel Positive Airway Pressure, cmH2O: centimeters of water (pressure), EPAP: expiratory positive airway pressure, FEV1: Forced expiratory volume in one second, FVC: Forced vital capacity, HMV: Home Mechanical Ventilation, IPAP: inspiratory positive airway pressure, MIP: maximal static inspiratory pressure, mmHg: millimeters of mercury (pressure), NOS: Not otherwise Specified, PaCO2: partial pressure of arterial carbon dioxide, ST: spontaneous/timed breath mode, TB: tuberculosis, TRD: Thoracic Restrictive Disorder

Table F.4 Thoracic Restrictive Disorders – Established home device use

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Hitzl, 2009^35^ Observational | HMV (pressure cycled assist control mode) in restrictive thoracic disease | -TRD NOS; -HMV initiated ≥3 months
Buyse, 2003^9^ Observational | HMV (volume or pressure cycled ventilator NOS) + oxygen | -Kyphoscoliosis NOS; -NIPPV use NOS

HMV: Home Mechanical Ventilation, NIPPV: Noninvasive positive pressure Ventilation, NOS: Not otherwise Specified, TRD: Thoracic Restrictive Disorder

Table F.5 Neuromuscular Disease - New initiation of home device

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Sanjuan-López, 2014^60^ Observational | HMV (PSV or ST) started after outpatient pulmonary evaluation | -ALS (El Escorial criteria); -hospital admission; -chronic respiratory failure by pulmonologist | | Increase in IPAP to target symptom relief. Monitored with daytime and nocturnal oximetry and blood gases.
Sanjuan-López, 2014^60^ Observational | HMV (PSV or ST) started in an emergency situation without prior outpatient pulmonary evaluation | -ALS (El Escorial criteria); -hospital admission; -chronic respiratory failure by pulmonologist | | Increase in IPAP to target symptom relief. Monitored with daytime and nocturnal oximetry and blood gases.
Pinto, 1995^53^ Observational | BPAP NOS | -ALS (El Escorial criteria); -bulbar features
Doménech-Clar, 2003^20^ Observational | BPAP NOS | -NMD NOS; -stable (no infection in past 3 months); -symptoms (fatigue, dyspnea, morning headache) | -PaCO2 >45 mmHg; or; -FVC <50%; or; -MIP <60 cm H2O; or; -nocturnal SaO2 < 88% for ≥ 5 consecutive minutes | IPAP increased (minimum 10 cmH2O) to target a normal PaCO2 or a decrease of at least 10 mmHg. (Titration occurred in hospital)
Nauffal, 2002^47^ Observational | BPAP NOS | -NMD NOS; -stable (no infection in past 3 months); -symptoms (fatigue, dyspnea, morning headache) | -PaCO2 >45 mmHg; or; -FVC <50%; or; -MIP <60 cm H2O; or; -SaO2 < 88% for ≥ 5 consecutive minutes by nocturnal oximetry | IPAP and EPAP titrated to maximize change of arterial blood gases. (Titration occurred in hospital)
Sancho, 2014^58^ Observational | HMV (volume cycled) versus BPAP ST | -ALS NOS; -symptoms (fatigue, dyspnea, orthopnea, morning headache) | -PaCO2 >45 mmHg; or; -FVC <50%; or; -MIP <60 cm H2O; or; -SaO2 < 88% for ≥ 5 consecutive minutes by nocturnal oximetry | Titration occurred in the hospital.
Sivori, 2007^63^ Observational | BPAP NOS | -ALS (El Escorial criteria); -symptomatic ventilatory impairment (dyspnea, morning headache, fatigue) | -PaCO2 >45 mmHg; or; -FVC <50%; or; -MIP <60 cm H2O; or; -nocturnal SaO2 < 88% for ≥ 5 consecutive minutes | IPAP adjusted to maintain SpO2 >92% (ranged 13-25 cmH2O). EPAP set from 5-9 cmH2O.
Coco, 2006^17^ Observational | BPAP ST | -ALS (El Escorial criteria); -symptomatic ventilatory impairment (dyspnea, morning headache, fatigue) | -PaCO2 >45 mmHg; or; -FVC <50%; or; -MIP <60 cm H2O; or; -nocturnal SaO2 < 88% for ≥ 5 consecutive minutes | Maximum tolerated IPAP and EPAP to target patient comfort, leaks, normal PaO2, PaCO2, SpO2, and symptom relief. IPAP started at 8-12 cmH2Oand EPAP started at 3-4c cmH2).
Bourke, 2006^7^ RCT | BPAP ST | -ALS NOS | -Orthopnea with Pimax <60%; or; -symptomatic daytime hypercapnia | IPAP and EPAP adjusted to optimize daytime arterial blood gases, nocturnal oximetry breathing room air, and increased use/duration of device.
Vitacca, 2017^68^ Observational | HMV/BPAP mix started in FVC≥80% (early) | -ALS NOS; -FVC≥80% | | Pressures adjusted to patient comfort, normalization of PaCO2, optimize nocturnal oximetry/polysomnography, and improve compliance. Backup rate set at 12 breaths/min. Preset tidal volume set at 5 ml/kg.
Vitacca, 2017^68^ Observational | HMV/BPAP mix started in FVC<80% (late) | -ALS NOS; -FVC<80%
Sancho, 2017^59^ Observational | HMV (volume assist control ventilation) | -ALS (El Escorial criteria); -symptomatic ventilatory impairment (dyspnea, orthopnea, fatigue, morning headache, daytime hypersomnolence, decreased cognitive function) | -PaCO2 >45 mmHg; and; -FVC <50%; and; -nocturnal SaO2 < 90% for ≥ 5% of time | Ventilator adjusted to target PaCO2<45mmHg, nocturnal SaO2 < 90% for <5% of time, optimize comfort, prevent air leaks.
Bertella, 2017^3^ RCT | BPAP volume assured pressure support ventilation | -ALS (definite via El Esocrial Criteria); -Stable disease (no respiratory infection in prior 3 months | -PaCo2>45mmHg, MIP<70%predicted, subjective respiratory discomfort in any position, FVC<70% predicted, or 20% decline in MIP or FVC over 3 months | Tidal volume was set, but to unclear settings. Respiratory rate set at 12 breaths/minute. IPAP set to maximal patient comfort. EPAP set to relieve obstructive events on polysomnogram. Settings adjusted to achieve maximal reduction in PaCO2. Device titrated in patient versus outpatient according to randomization.
Tsolaki, 2011^66^ Observational | BPAP ST | -NMD NOS; -Stable (no acute exacerbation in prior 4 weeks); -Symptoms of nocturnal hypoventilation (fatigue, dyspnea, morning headaches) | -PaCO2 ≥45mmHg; -pH>7.35 | Patients were hospitalized for 2–3 days during the initial application of NIV, in order to ensure maximal compliance. The modality of NIV was pressure support ventilation delivered by a variable positive airway pressure device (VPAP III ST, ResMed, Sydney, N.S.W., Australia), set in the spontaneous/timed mode with a backup respiratory rate of 8–14 breaths / min. Inspiratory and expiratory positive airway pressures (IPAP and EPAP, respectively) were adjusted according to the patient’s comfort and synchrony with the ventilator and a marked reduction in the use of accessory muscles. For the first 2 h from the initiation of ventilation the patient was observed by a pulmonologist and a fully trained nurse, in order to assure a decrease in accessory respiratory muscle use and respiratory rate, check the patient’s comfort of mask ventilation and possible air leaks of the system. Supplemental oxygen was added as needed in order to maintain oxygen saturation between 88 and 92%. Arterial blood gases were measured 1 h after the initiation of ventilation. A 5% decrease in Pa CO 2 values was considered as adequate ventilatory support.
Aboussouan, 1997^1^ Observational | HMV/BPAP mix | -ALS via el Escorial criteria; -dyspnea on exertion or or orthopnea or FVC < 60% predicted. | - PaCO2 ≥ 45 mmHg | The devices used were a volume-controlled ventilator (PLV-100, Life Care Products, Lafayette, Colorado) in assist-control mode or a bilevel positive-pressure device (BiPAP, Respironics, Inc., Murrysville, Pennsylvania) in spontaneous-timed mode (the latter was added as an option after September 1994). Patients were ventilated in the supine position while in clinic. Tidal volume (for the volume-controlled ventilator) or pressure (for the bilevel positive-pressure device) were initially adjusted for chest rise, leaks, and patient comfort and were adjusted on subsequent visits to control hypercapnia and dyspnea. The ultimate choice of a device was made by the patient after the two devices had been sampled. Patients were instructed to use noninvasive positivepressure positivepressure ventilation nightly as tolerated and as necessary in the daytime. On subsequent visits, alternate interfaces were used for mask-related problems, nasal steroid sprays were used for nasal congestion, and suction machines or mechanical insufflation- exsufflation were used for clearance of secretions. Tolerance was defined as the ability to sleep nightly while receiving noninvasive positive-pressure ventilation for at least 4 consecutive hours.
Farrero, 2005^26^ Observational | HMV/BPAP mix | -ALS NOS; -Symptoms (orthopnea); -FVC ≤50% predicted or a decrease in FVC of ≥ 500 mL on two consecutive visits | -Desaturations in nocturnal pulse oximetry (arterial oxygen saturation, <90% during 5 consecutive min); Or; PaCO2 >45 mm Hg | A volume ventilator (LIFECARE PLV100; Respironics; Murrysville, PA) was used in all cases of invasive ventilation, whereas either a volume ventilator (LIFECARE PLV100; Respironics; and PV 501; BREAS Medical; Gothenburg, Sweden) or a bilevel pressure ventilator (BiPAP; Respironics; and Sullivan VPAP ST II; ResMed Ltd; Abingdon, UK) was used for NIV. Interfaces included nasal masks (customized or commercial) with a chinstrap (to minimize oral leaks), mouthpiece, or facemask. The choice of ventilator and interface was based on the adaptation of the patient and the number of hours of ventilation required. Treatment with HMV was initiated during a hospital admission, and ventilation parameters were adjusted to achieve comfort as well as adequate ventilation according to daytime arterial blood gas levels and nocturnal oximetry measurements.

ALS: amyotrophic lateral sclerosis, BPAP: Bilevel Positive Airway Pressure, cmH2O: centimeter of water (pressure), EPAP: expiratory positive airway pressure, FVC: Forced vital capacity, HMV: Home Mechanical Ventilation, IPAP: inspiratory airway pressure, MIP: maximal static inspiratory pressure, mmHg: millimeters of mercury (pressure), NMD: Neuromuscular Disease, NOS: Not otherwise Specified, PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, Pimax: maximal inspiratory mouth pressures, PSV: Pressure support ventilation, RCT: randomized controlled trial, SaO2: arterial blood oxygen saturation, SpO2: peripheral capillary oxygen saturation, ST: spontaneous/timed breath mode

Table F.6 Neuromuscular Disease – Established home device use

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Pinto, 2010^54^ Observational | BPAP ST + weekly telemonitoring versus BPAP ST without weekly telemonitoring | -ALS NOS; -home BPAP use; -FVC ≥75% | -PaCO2 ≤ 45 mmHg; -PaO2 ≥80 mmHg | Increase in IPAP to achieve normal breathing patterns, daytime and nocturnal SaO2 > 95%. Backup rate set slightly lower than the patient’s own respiratory frequency. (Titration occurred in hospital or outpatient clinic)
Gonzalez-Bermejo, 2013^32^ Observational | BPAP ST | -ALS NOS; -home BPAP with 4 hours/night minimal adherence | | Maximum tolerated IPAP to target patient comfort, leaks, and efficiency of ventilation, relieve symptoms, and achieve normal daytime PaO2, PaCO2, and SpO2. EPAP ranged from 3-5 cmH2O.

ALS: amyotrophic lateral sclerosis, BPAP: Bilevel Positive Airway Pressure, cmH2O: centimeters of water (pressure),, EPAP: expiratory positive airway pressure, FVC: Forced vital capacity, IPAP: inspiratory positive airway pressure, mmHg: millimeters of mercury (pressure), PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, NOS: Not otherwise Specified, SaO2: arterial blood oxygen saturation, SpO2: peripheral capillary oxygen saturation, ST: spontaneous/timed breath mode

Table F.7 Obesity Hypoventilation Syndrome - New initiation of home device

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Howard, 2016^36^ RCT | BPAP ST versus CPAP | -OHS (BMI >30, daytime PaCO2 >45 mmHg, other causes of hypoventilation ruled out including NMD, chest wall abnormalities, respiratory depressant medications, COPD, FEV1/FVC <70% after bronchodilators) | -PaCO2 >45 mmHg (daytime); -pH 7.35-7.45 | BPAP ST: IPAP and EPAP titrated to overcome obstructive events and nocturnal hypoventilation CPAP: Fixed pressure titrated to overcome obstructive events in polysomnography
Salturk, 2015^57^ Observational | BPAP ST | -OHS (BMI>30, daytime PaCO2 ≥ 45 mmHg and symptoms of hypercapnia, no other cause of hypoventilation) | -PaCO2 >45 mmHg (daytime) | IPAP titrated to achieve “desired tidal volume” (maximum 30 mbar)
Masa, 2000^39^ Observational | HMV (volume cycled or pressure cycled) | -OHS (BMI>33; PaCO2 >47 mmHg for 3 months; weight loss failure; refusal for weight loss surgery); -FEV1/FVC ≥65%; -Apnea-hypopnea index ≤ 20 events/hour | -PaCO2 >47 mmHg for at least 3 months | Ventilator parameters adjusted to target maximum reduction in PaCO2 as well as patient tolerance, air leakage, and nocturnal saturation >90%. Patient initially treated with volume-cycled ventilator. Patients with poor compliance to volume-cycled ventilator were switched to a bilevel pressure ventilator. (Titration occurred in hospital over 3-7 days)
Castillejo, 2014^11^ Observational | BPAP ST in OHS without OSA compared to BPAP ST in OHS with OSA | -OHS (BMI >30, daytime PaCO2 >45 mmHg, nighttime PaCO2 > 50 mmHg, with or without associated OSA, other causes of hypoventilation excluded (FEV/FVC ratio <70%, NMD with respiratory involvement, respiratory disease other than OHS) | -PaCO2 >45 mmHg (daytime, PaCO2 > 50 mmHg (nighttime) | IPAP adjusted during daytime to target PaCO2 < 45 mmHg or a decrease from baseline by 5 mmHg with a mean SaO2 > 90% (IPAP range 16-24 cmH2o). EPAP 6-10 cmH2O. Pressures further adjusted at nighttime via polysomnography.
Masa, 2015^40,^ ^41^ RCT | HMV/BPAP mix (all with bilevel pressure with assured volume) versus CPAP (fixed pressure) | -OHS (BMI ≥ 30; stable PaCO2 ≥ 45 mmHg; pH ≥ 7.35; no clinical worsening in prior 2 months; other causes of hypoventilation ruled out including no evidence of COPD, NMD, narcolepsy); -Severe OSA (apnea-hypopnea index ≥30); -Correctly executed 30min CPAP/NIPPV treatment trial test | -PaCO2 ≥ 45 mmHg; -pH ≥ 7.35 | HMV/BPAP mix: IPAP maximum tolerated to target reduction in PaCO2, normal SaO2, patient tolerance, target volume of 5-6 ml/kg of actual body weight. IPAP range 18-22 mmHg. EPAP range 4-8 mmHg. Pressures further adjusted in polysomnography to treat apneas and hypopneas.; CPAP: Polysomnography to eliminate apneas, hypopneas, thoracoabdominal paradoxical movement, flow limitation, and snoring.
Borel, 2011^6^ RCT | BPAP ST | -OHS (BMI >30; daytime PaCO2 ≥ 45 mmHg, other causes of hypoventilation ruled out including airway obstruction, scoliosis, cardiac failure, progressive NMD) | -PaCO2 ≥ 45 mmHg (daytime) | (Titration occurred in hospital over 3-4 nights)
Murphy, 2012^45^ RCT | BPAP (volume assured pressure support ventilation) versus BPAP ST | -OHS (BMI>40, daytime chronic PaCO2 >6 kPa, pH >7.35), absence of other identifiable hypoventilation cause, FEV1/FVC >70%, FVC <70%; -Stable disease | -PaCO2 >6 kPa (45 mmHg); -pH >7.35 (daytime) | Titration according to a protocol with goal to abolish apneas, snoring, and “to achieve adequate nocturnal respiratory control” (See online data supplement of primary article)
Piper, 2008^55^ RCT | BPAP S versus CPAP | -OHS (BMI≥30, PaCO2 ≥ 45 mmHg [awake, stable], absence of another cause for hypercapnia, FEV1/FVC ≥ 70%) | -PaCO2 ≥45 mmHg; -pH ≥7.34 (daytime, stable); Excluded during CPAP titration study:; -SaO2 <80% for 10 minutes in absence of apnea; -TcCO2 during REM ≥10mmHg; -increase in afternoon to morning PaCO2 ≥10mmHg in patients with awake PaCO2 >55 mmHg
Blankenburg, 2017^5^ | HMV (pressure controlled ventilation or pressure support ventilation) | -OHS (BMI>30, PaCO2 >6.7kPa[50mmHg], symptoms of hypercapnia NOS), absence of another cause for hypercapnia | -PaCO2>7.0kPa (53mmHg); -pH>7.35 | Goal of titration was normal PaCO2 as well as patient tolerability of NIPPV. Titration started in pressure controlled ventilation mode. If pressure controlled ventilation was not achievable, pressure support ventilation was used. Inspiratory pressure was set to relieve “air hunger” on inspiration or to reach a tidal volume ≥800mL. PEEP was increased to maximally tolerated. Respiratory rate was set at 2 breaths/minute above the spontaneous respiratory rate.
Tsolaki, 2011^66^ Observational | BPAP ST | -OHS NOS; -Stable (no acute exacerbation in prior 4 weeks); -Symptoms of nocturnal hypoventilation (fatigue, dyspnea, morning headaches); -BMI > 30; -persistent hypoventilation despite overnight trial of CPAP | -PaCO2 >45mmHg; -PaO2 <70mmHg; -pH>7.35 | Patients were hospitalized for 2–3 days during the initial application of NIV, in order to ensure maximal compliance. The modality of NIV was pressure support ventilation delivered by a variable positive airway pressure device (VPAP III ST, ResMed, Sydney, N.S.W., Australia), set in the spontaneous/timed mode with a backup respiratory rate of 8–14 breaths / min. Inspiratory and expiratory positive airway pressures (IPAP and EPAP, respectively) were adjusted according to the patient’s comfort and synchrony with the ventilator and a marked reduction in the use of accessory muscles. For the first 2 h from the initiation of ventilation the patient was observed by a pulmonologist and a fully trained nurse, in order to assure a decrease in accessory respiratory muscle use and respiratory rate, check the patient’s comfort of mask ventilation and possible air leaks of the system. Supplemental oxygen was added as needed in order to maintain oxygen saturation between 88 and 92%. Arterial blood gases were measured 1 h after the initiation of ventilation. A 5% decrease in Pa CO 2 values was considered as adequate ventilatory support.
Masa, 2016^42^ RCT | BPAP volume assured pressure support ventilation | -OHS (BMI ≥ 30 kg/m2, no COPD, no NMD, no TRD, no narcolepsy, no restless leg syndrome); -Stable disease | -PaCO2 ≥ 45 mmHg, (daytime, awake); -pH ≥ 7.35 | The ventilator mode was set at bilevel pressure with assured volume (ie, volume targeted pressure support). While the patient was awake, the expiratory positive airway pressure (EPAP) was initially set between 4 and 8 cm H2O and the inspiratory positive airway pressure (IPAP) was set between 18 and 22 cm H2O (EPAP included). The pressures were adjusted to obtain normal oxygen saturation, if possible, as measured by pulse oximetry and patient tolerance. The backup respiratory rate was initially adjusted to 12–15 breaths/min (close to the spontaneous respiratory rate, if possible) and the target volume was set at between 5 and 6 mL/kg of actual weight, allowing for an increase in the maximum pressure over the previously minimum IPAP, if necessary. A check of mechanical ventilation phases (trigger, pressurisation and ending) was also performed to avoid asynchronies and to refine the setting. After 30 min of continuous use with patient adaptation and an adequate patient–ventilator interaction, an ABG analysis was performed. The PaCO2 result was used to adjust the ventilator parameters. The final adjustment was performed by means of conventional PSG, with an increase in EPAP for obstructive apnoeas and an increase in IPAP for hypopnoeas, flow limitation, snoring or non-apnoeic hypoventilation, with the goal of achieving normalisation of oxygen saturation or the maximal pressure tolerated was reached. No changes were made in the assured volume during this nocturnal titration
Perez de Llano, 2005^52^, Observational | HMV/BPAP mix | -OHS, BMI > 30,, FEV1/FVc < 70%, absence of other respiratory disorder such as kyphoscoliosis or diaphragmatic paralysis | -PaCO2 ≥ 50 mmHg | Treatment with NIPPV was started in all patients who experienced respiratory failure presumed to be secondary to OHS. Patients were treated initially with bilevel pressure devices (DP-90 and Eclipse Delta; Taema; Antony, France; and PV-102; BREAS; Gothenburg, Sweden), but, in those patients who did not achieve sufficient improvement with this system, we subsequently changed over to a volume-cycled ventilator (Home 2; Airox; Pau, France). The interface used in all patients was a commercially available nasal mask that was secured with head straps. Initially, positive expiratory pressure (PEP) was set at 6 cm H2O, and the positive inspiratory pressure (PIP) was set at 10 cm H2O. PIP was gradually adjusted upward as tolerated. Oxygen was administered, when needed, through the mask until the arterial oxygen saturation (Sao2) was ≥ 90%. Daytime sessions lasted from 3 to 6 h with pauses of 3 h to allow the administration of conventional medication and feeding. Nighttime sessions were continuous, provided that patient tolerance permitted. When arterial blood gas levels were stable (ie, pH > 7.35), daytime NIPPV therapy was stopped. We employed daytime arterial blood gas measurements and overnight pulse oximetry to determine the NIPPV settings. We gradually increased PEP until the disappearance of repetitive dips in Sao_2_ was achieved. PIP was then increased until an acceptable level of steady saturation was obtained. We considered treatment with NIPPV to be successful if orotracheal intubation had been avoided in patients with an initial pH of < 7.34 and, for the entire group, when the mean Sao_2_ during overnight oximetry was ≥ 88% and diurnal Paco_2_ was ≤ 65 mm Hg with a normal pH. Then, the patients could be discharged from the hospital, and they were instructed to employ NIPPV during the night with the final settings obtained.
Priou, 2010,^56^ Observational | BPAP | -OHS (PaCO2> 45 mm Hg in the absence of any other cause of hypoventilation on the basis of clinical xamination, chest radiograph, and pulmonary function tests (eg, COPD [FEV 1 to vital capacity ratio, 70%]). | PaCO2> 45 mm Hg | Expiratory positive airway pressure (EPAP) and inspiratory positive airway pressure (IPAP) were adapted by 2 cm H_2_O steps using repeated oximetry and arterial blood gases (ABG) to alleviate OSA-related desaturations, to improve mean nocturnal oxygen desaturation index (Sao_2_), and to achieve a maximal reduction in daytime Paco_2_. Supplemental oxygen was added to NPPV in patients with persistent nocturnal hypoxia (as defi ned arbitrarily by ≥ 20% of time with Sao_2_, < 90%) despite a delta between EPAP and IPAP of at least 10 cm H_2_O as tolerated by the patient.

BPAP: Bilevel Positive Airway Pressure, COPD; chronic obstructive pulmonary disease, CPAP: Continuous Positive Airway Pressure, BMI: Body Mass Index, EPAP: expiratory positive airway pressure, FEV1: Forced expiratory volume in one second, FVC: Forced vital capacity, HMV: Home Mechanical Ventilation, IPAP: inspiratory positive airway pressure, kPa: kilopascal, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive Positive Pressure Ventilation, NMD: Neuromuscular Disease, OHS: Obesity hypoventilation syndrome, OSA: Obstructive sleep apnea, PaCO2: partial pressure of arterial carbon dioxide, S: spontaneous mode, SaO2: arterial blood oxygen saturation, ST: spontaneous/timed breath mode, TcCO2: transcutaneous carbon dioxide

Table F.8 Other Respiratory Diseases - New initiation of home device

Author, Year, Study Design | Disease | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Salturk, 2015^57^ Observational | Diffuse parenchy mal lung disease | BPAP ST | -Diffuse parenchymal lung disease (sequela of TB or bronchiectasis with hypoxemia and hypercapnia) | | IPAP titrated to achieve “desired tidal volume” (maximum 30 mbar)

BPAP: Bilevel Positive Airway Pressure, IPAP: inspiratory positive airway pressure, ST: spontaneous/timed breath mode, TB: tuberculosis

Table F.9 Other Respiratory Diseases – Established home device use

Author, Year, Study Design | Disease | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Benhamou, 1997^2^ Observational | Diffuse bronchiect asis | HMV (volume cycled) | -Diffuse bronchiectasis; -Home HMV; -LTOT | | Target PaO2 > 9kPa (67 mmHg) without deterioration in PaCO2.

HMV: Home Mechanical Ventilation, kPa: kilopascal, LTOT: long term oxygen therapy, mmHg: millimeters of mercury (pressure), PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide

Table F.10 Mixed diseases – New initiation of home device

Author, Year, Study Design | Disease | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Windisch, 2006^69^ Observational | TRD, OHS | HMV with pressure controlled ventilation (PCV) mode | -COPD NOS; -NIPPV in hospital admission; -Stable (no worsening symptoms in prior 2 weeks, respiratory rate <30 breaths/minute, no signs of current respiratory infection, no changes in symptoms or medications in prior 3 months) | -pH≥7.35 | Maximum tolerated IPAP to target a maximum decrease in PaCO2
Hazenberg, 2014^33^ RCT | NMD, TRD | HMV (pressure or volume control) started at home | -NMD or thoracic cage disorder; -Stable disease without acute respiratory failure | -PaCO2 >6.0 kPa (>45 mmHg) (daytime) | Maximum tolerated IPAP to target a target tidal volume of 8-10 ml/kg and a respiratory rate close to the baseline respiratory rate, reduce snoring, patient comfort. Titration of ventilator parameters to achieve normal PaCO2 and PaO2.; (Titration occurred at home)
Hazenberg, 2014^33^ RCT | NMD, TRD | HMV (pressure or volume control) started in the hospital | -NMD or thoracic cage disorder; -Stable disease without acute respiratory failure | -PaCO2 >6.0 kPa (>45 mmHg) (daytime) | Maximum tolerated IPAP to target a target tidal volume of 8-10 ml/kg and a respiratory rate close to the baseline respiratory rate, reduce snoring, patient comfort. Titration of ventilator parameters to achieve normal PaCO2 and PaO2.; (Titration occurred at the hospital)
Munoz, 2005^44^ Observational | NMD, TRD | HMV volume assist/control mode versus HMV volume control mode | -Hospital admission with chronic hypercapnic respiratory failure to NMD (ALS excluded) or kyphoscoliosis or post TB sequelae | -PaCO2 > 45 mmHg (daytime, stable) | The tidal volume, respiratory frequency, and the I/E ratio were adjusted individually according to tolerance, air leaks, and ventilatory response.
Chiang, 2003^13^ RCT | COPD, Other | BPAP NOS | -COPD or asthma or bronchiectasis; -hospital readmission due to respiratory cause; -Daytime sleepiness or morning headache | -PaCO2 > 50 mmHg (daytime rest); -SpO2 < 88% for more than 5 consecutive minutes while on usual oxygen during polysomnography | IPAP and EPAP and volumes set to target optimal daytime PaCO2

BPAP: Bilevel Positive Airway Pressure, COPD; chronic obstructive pulmonary disease, EPAP: expiratory positive airway pressure, HMV: Home Mechanical Ventilation, IPAP: inspiratory positive airway pressure, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive Positive Pressure Ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OHS: Obesity hypoventilation syndrome, PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, RCT: randomized controlled trail, SpO2: peripheral capillary oxygen saturation, TB: tuberculosis, TRD: Thoracic Restrictive Disorder

Table F.11 Mixed diseases – Established home device use

Author, Year, Study Design | Disease | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Crespo, 2009^18^ Observational | COPD, TRD, NMD, OHS, Other | HMV (pressure or volume NOS) | -home HMV use; -stable respiratory disease (all cause)

COPD: chronic obstructive pulmonary disease, HMV: Home Mechanical Ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OHS: Obesity hypoventilation syndrome, TRD: Thoracic Restrictive Disorder

## KQ2 In each of the disease groups, what is the effect of HMV, a BPAP, or a CPAP use on patient outcomes?

Table F.12 COPD – Effectiveness of home devices

Author, Year, Study Design | Disease | Inclusion/Exclusio n Criteria | Device And Settings Used (Group) | Duration Of Device Use In Home Setting | Conclusion
Vasquez, 2017^67^ Observational | COPD | Inclusion: COPD (ICD-9); age ≥40 years | 1) BPAP NOS | Longest duration: 6 months | The HMV group had significantly more reduction of mortality than those with CPAP (p<0.001) or BPAP (p<0.001), and more reduction on COPD-related hospitalization than the CPAP group (p=0.01).
Vasquez, 2017^67^ Observational | COPD | Inclusion: COPD (ICD-9); age ≥40 years | 2) CPAP NOS | Longest duration: 6 months | The HMV group had significantly more reduction of mortality than those with CPAP (p<0.001) or BPAP (p<0.001), and more reduction on COPD-related hospitalization than the CPAP group (p=0.01).
Vasquez, 2017^67^ Observational | COPD | Inclusion: COPD (ICD-9); age ≥40 years | 3) HMV NOS | Longest duration: 6 months | The HMV group had significantly more reduction of mortality than those with CPAP (p<0.001) or BPAP (p<0.001), and more reduction on COPD-related hospitalization than the CPAP group (p=0.01).
Murphy, 2017^46^, RCT | COPD | Inclusion: COPD (FEV1 < 50%, FEV1/FVC ratio <60%, smoking history >20 pack years); AECOPD requiring hospital admission and acute NIPPV; PaCO2 >53 mmHg; PaO2 <55 mmHg or PaO2 < 60 mmHg with polycythemia, pulmonary hypertension or cor pulmonale; >30% sleep time with SaO2 <90%; pH >7.30 room air; Exclusion: intubated during AECOPD, current home NIPPV use, cognitive impairment, unstable psychiatric morbidity, undergoing renal replacement therapy, unstable coronary artery syndrome, age < 18 years, homeless, BMI >35, OSA. | 1) BPAP ST + home oxygen | Longest duration: 12 months | The BPAP ST group had significantly fewer AECOPD than the home oxygen alone group (rate ratio, 0.66; 95%CI, 0.46- 0.95, p = 0.03). Twelve month mortality was not significantly different between the two groups (HR, 0.67; 95%CI, 0.34- 1.30, p = 0.23). Quality of life at 12 months was not significantly different between the groups.
Murphy, 2017^46^, RCT | COPD | | 2) Home oxygen | Longest duration: 12 months
Oscroft, 2014^50^, RCT | COPD | Inclusion: COPD (FEV1 <50%, FEV1/FVC ratio <70%, TLC>80%, smoking history > 20 pack years); daytime PaCO2 >7 kPa and pH >7.35 or PtcCO2 >9 kPa; Exclusion: Age>80 years, other respiratory disease, BMI>40, significant OSA. | 1) BPAP volume assured pressure support ventilation | 3 months | The BPAP volume assured pressure support ventilation group had significantly shorter hospital stay than the BPAP ST group (3.3 days vs. 5.2 days, p=0.02). There was no significant difference on mortality (OR=0.47, 95% CI: 0.04 to 5.69; p=0.56), exercise tolerance, dyspnea, quality of life, or sleep quality after 3-month followup.
Oscroft, 2014^50^, RCT | COPD | | 2) BPAP ST | 3 months
Paone, 2014^51^, Observational | COPD | Inclusion: COPD (FEV1 <50%, FEV1/FVC ratio <70%, <20% improvement bronchodilator response); NIPPV during hospital stay; PaCO2 > 50 mmHg immediately after awakening from a night without NIPPV; Exclusion: Significant comorbidities affecting survival (cancer, left ventricular heart failure, unstable angina), psychiatric disorders affecting ability to undergo NIPPV, other chronic respiratory disease, history of OSA, BMI>40, systemic corticosteroids. | 1) BPAP ST + Home oxygen | 24 months | The BPAP ST + home oxygen group had significantly less hospital admissions (Rate Ratio= 0.50; 95% CI: 0.35 to 0.71; p<0.01). There was no significant difference on mortality (27.1% vs. 22.2%; p=0.59).
Paone, 2014^51^, Observational | COPD | | 2) Home oxygen | 24 months | The BPAP ST + home oxygen group had significantly less hospital admissions (Rate Ratio= 0.50; 95% CI: 0.35 to 0.71; p<0.01). There was no significant difference on mortality (27.1% vs. 22.2%; p=0.59).
Galli, 2014^29^, Observational | COPD | Inclusion: AECOPD (ICD-9); PaCO2 > 45 mmHg; NIPPV during hospital stay; Exclusion: discharged to hospice. | 1) BPAP NOS | Longest duration: 6 months | BPAP was associated with significantly fewer hospital readmissions (p < 0.0001) and ICU readmissions. There was no significant difference on mortality at 6-month followup (10% vs. 19%, p=0.13).
Galli, 2014^29^, Observational | COPD | Inclusion: AECOPD (ICD-9); PaCO2 > 45 mmHg; NIPPV during hospital stay; Exclusion: discharged to hospice. | 2) No BPAP | Longest duration: 6 months | BPAP was associated with significantly fewer hospital readmissions (p < 0.0001) and ICU readmissions. There was no significant difference on mortality at 6-month followup (10% vs. 19%, p=0.13).
Bhatt, 2013^4^, RCT | COPD | Inclusion: COPD (FEV/FVC < 70%, smoking >10 pack years); no exacerbations in past 4 weeks; low clinical probability of OSA; Exclusion: Congestive heart failure, OSA, chronic respiratory conditions other than COPD, age<35 years, diseases limiting life expectancy <2 years, active malignancies in previous 2 years, process precluding a nasal mask. | 1) BPAP NOS | Longest duration: 6 months | BPAP was associated with significantly higher quality of life scale (measured by Chronic Respiratory disease Questionnaire) than the no BPAP group (p=0.04). There was no significant difference on exacerbations, exercise tolerance (6-minute walk distance test), dyspnea, and sleep quality.
Bhatt, 2013^4^, RCT | COPD | | 2) No BPAP | Longest duration: 6 months
Duiverman, 2011^22,^ ^23^, RCT | COPD | Inclusion: COPD (FEV1 <50%, FEV1/FVC < 70%, GOLD stage III/IV); age 40-76 years; no exacerbation in past 4 weeks; daytime PaCO2 >6.0 kPa; Exclusion: cardiac/neuromusc ular disease limiting exercise tolerance, pulmonary rehabilitation in past 18 months, prior NIPPV, apnea-hypopnea index ≥10h. | 1) BPAP ST + Pulmonary rehabilitation | Longest duration: 24 months | At 24 months, BPAP was associated with significantly better outcomes, including dyspnea (Medical Research Council −0.4; 95% CI: −0.8 to −0.0), 6-minute walk distance test (77.3 meters, 95% CI: 46.4 to 108.0), and activities of daily living (Groningen Activity and Restriction Scale, −3.8, 95% CI: −7.4 to −0.4). No significant difference was found on mortality (OR= 0.94, 95% CI: 0.25 to 3.57), quality of life (Chronic Respiratory Questionnaire) (−1.3; 95% CI: −9.7 to 7.4), exacerbation frequency, and hospitalization rate.
Duiverman, 2011^22,^ ^23^, RCT | COPD | | 2) Pulmonary rehabilitation alone | Longest duration: 24 months
Oscroft, 2010^48^, Observational | COPD | Inclusion: COPD (FEV1 <50%, FEV1/FVC ratio <70%, smoking history >20 pack years); AECOPD requiring hospital admission; daytime PaCO2 >7.5 kPa with pH 7.35-7.45 or daytime PaCO2 >6.5 kPa with pH 7.35-7.45 with PtcCO2 >9 kPa; Exclusion: Age>80 years, other respiratory disease, BMI>35, significant OSA, tracheostomy, impaired left ventricular function. | 1) BPAP ST started in AECOPD | 28.6 months, 95% CI 10.9-46.8 months, Median 52.4 months | The BPAP ST started in AECOPD group had significantly shorter median survival time than the stable group (28.6 months vs. 52.6 months, p=0.03).
Oscroft, 2010^48^, Observational | COPD | | 2) BPAP ST started in stable COPD | 28.6 months, 95% CI 10.9-46.8 months, Median 52.4 months | The BPAP ST started in AECOPD group had significantly shorter median survival time than the stable group (28.6 months vs. 52.6 months, p=0.03).
Cheung, 2010^12^ RCT | COPD | Inclusion: AECOPD requiring hospital admission and NIPPV, pH <7.35, PaCO2 > 6 kPa; Exclusion: Active smokers, RF from other cause, pneumonia, transmissible infections, long-term corticosteroid use, comorbidity giving life expectancy <1 year, significant OSA, already on home NIPPV | 1) CPAP | Longest duration: 12 months | 7 out of 23 patients in the BPAP group developed severe COPD exacerbation with AHRF while 14 out of 26 patients in the COPD group had severe exacerbation with AHRF (OR= 0.38, 95% CI: 0.12 to 1.22; p=0.10). 8 patients in the BPAP group withdrew from the study, compared to 4 patients in the CPAP group (OR= 2.93; 95% CI: 0.75 to 11.52; p=0.12). No significant difference of number of adverse events were found between the two groups (p=0.29).
Cheung, 2010^12^ RCT | COPD | | 2) BPAP ST | Longest duration: 12 months
McEvoy, 2009^43^ RCT | COPD | Inclusion: COPD (FEV1<50% or <1.5L, bronchodilator response <20%, FEV1/FVC ratio <60%); PaCO2 <46 mmHg at least twice in the prior 6 months during clinical stability; LTOT for ≥3 month; Age<80 years; Exclusion: current smokers, significant comorbidities (malignancies, left ventricular HF, unstable angina) likely affecting 2 year survival, severe psychiatric disorder impairing ability to comply to NIPPV, BMI>40, evidence of sleep apnea. | 1) BPAP S + Oxygen | Longest duration: 12 months | No significant difference was found on survival (unadjusted HR: 0.82; 95% CI 0.53 to 1.25, OR= 0.71; 95% CI: 0.36 to 1.38), quality of life and hospitalization rates.
McEvoy, 2009^43^ RCT | COPD | | 2) Oxygen alone | Longest duration: 12 months | No significant difference was found on survival (unadjusted HR: 0.82; 95% CI 0.53 to 1.25, OR= 0.71; 95% CI: 0.36 to 1.38), quality of life and hospitalization rates.
Casanova^10^, 2000 RCT | COPD | Inclusion: COPD (FEV1 <45%, FEV1/FVC <70%, smoking >20 pack years, TLC ≥80%); stable disease (no AECOPD in past 3 months); age 45-75 years; Exclusion: current smoker, OSA, apnea-hypopnea index >10/hour, other etiologies of chronic airway obstruction, significant comorbidities. | 1) BPAP S + Standard care | Longest duration: 12 months | There were no significant differences on mortality, the number of acute exacerbations, hospital admissions, intubations, dyspnea (Medical Research Council).
Casanova^10^, 2000 RCT | COPD | | 2) Standard care | Longest duration: 12 months | There were no significant differences on mortality, the number of acute exacerbations, hospital admissions, intubations, dyspnea (Medical Research Council).
Garrod, 2000^30^ RCT | COPD | Inclusion: COPD (FEV1 <50%, bronchodilator response <15%); exercise intolerance due to dyspnea, no prior NIPPV; Exclusion: unstable angina, intermittent claudication, other mobility-limiting conditions. | 1) BPAP S + Pulmonary rehabilitation | | The BPAP S plus pulmonary rehabilitation had significantly better outcomes on quality of life (Chronic Respiratory Disease Questionnaire, 12.3; 95% CI: 1.19 to 23.4; p=0.03), and shuttle walk test (72 meters, 95% CI: 12.9 to 131 meters). There was no difference on activities of daily living, and dyspnea.
Garrod, 2000^30^ RCT | COPD | | 2) Pulmonary rehabilitation
Clini, 1998^15^ Observational | COPD | Inclusion: COPD, prior smokers, LTOT ≥12 month; stable disease (no AECOPD in prior 4 weeks); stable PaCO2; pH>7.35; PaO2 < 8 kPa (daytime room air), PaCO2 >6 kPa (daytime room air); ≥1 ICU admission due to AECOPD in prior 2 years; Exclusion: other organ failure, cancer, suspected OSA. | 1) BPAP ST + Oxygen | Longest duration: 2 months | The BPAP plus oxygen group was found to have significantly more changes in 6-minute walk distance test than the oxygen group (p<0.01). There were no significant differences on mortality (OR=0.79, 95% CI; 0.25 to 2.45); or changes in dyspnea (American Thoracic Society).
Clini, 1998^15^ Observational | COPD | | 2) Oxygen | Longest duration: 2 months
Clini, 1996^14^, Observational | COPD | Inclusion: COPD, LTOT ≥18 mo.; chronic PaCO2 >6.7 kPa (50 mmHg); ≥1 hospital admission due to AECOPD in prior 18 months; Exclusion: suspected OSA, ≥15% bronchodilator response, comorbidities making patients unsuitable for long-term trials. | 1) BPAP ST + Home care + Oxygen | Longest duration: 18 months | During the 18 month followup, there was no difference on mortality (23% vs. 18%), ICU admissions (rate ratio: 0.29; 95% CI: 0.06 to 1.38) and hospital admissions (rate ratio: 0.88, 95% CI: 0.44 to 1.77).
Clini, 1996^14^, Observational | COPD | | 2) Home care + Oxygen | Longest duration: 18 months
Zhou, 2017^70^ RCT | COPD | Inclusion: COPD (Gold Stage III/IV); chronic hypercapnia (measured during daytime at rest with no oxygen or NIPPV); age≥40 years; Exclusion: Abnormalities of lung/thorax other than COPD, previously treated on NIPPV, OSA, severe HF, severe arrhythmias, unstable angina, malignant comorbidities, COPD w/ OSA overlap syndrome, impairments that could affect ability for followup. | 1) BPAP ST | 3 months | Significantly more patients in the BPAP ST group achieved the minimum clinical improvement on 6-minute walk distance test (38.2% vs. 18.2%, p=0.02) than the standard care group.; No significant difference was found on mortality, and quality of life (Severe Respiratory Insufficiency Questionnaire).
Zhou, 2017^70^ RCT | COPD | | 2) Standard care | 3 months
Marquez-Martin, 2014^38^ RCT | COPD | Inclusion: COPD (FEV1 <50%);; PaO2 < 60 mmHg (chronic); PaCO2 > 45 mmHg (chronic). | 1) BPAP ST | 3 months | In 6-minute walk distance test, patients in the BPAP ST group increased by 40 meters (p=0.01); 32 meters in the exercise group (p=0.01) and 83 meters in the combined group (p<0.001). No significant difference was found between the groups on 6-minute walk distance test, and dyspnea (Medical Research Council, 1 vs.1.5 vs.1, p=0.6), and quality of life (Chronic Respiratory Disease Questionnaire, 4.6 vs. 5.61 vs.5.26, p=0.06).
Marquez-Martin, 2014^38^ RCT | COPD | Inclusion: COPD (FEV1 <50%);; PaO2 < 60 mmHg (chronic); PaCO2 > 45 mmHg (chronic). | 2) Exercise program | 3 months
Köhnlein, 2014^37^ RCT | COPD | Inclusion: COPD (GOLD IV); clinically stable (no AECOPD in prior 4 weeks); PaCO2 ≥ 7 kPa (51.9 mmHg); pH ≥ 7.35 (rest); Exclusion: Thorax/lung abnormalities other than COPD, BMI≥35, other conditions resulting in hypercapnia, previously initiated NPPV, malignant comorbidities, severe HF, unstable angina, severe arrhythmias. | 1) BPAP ST + Standard care | 12 months | The BPAP group was found to have significantly less mortality rate at 1 year (HR=0.24, 95% CI: 0.11 to 0.49). The difference was significant after 1 year. The BPAP group had better outcomes on quality of life (Saint George’s Respiratory Questionnaire, 6.2, 95% CI: 0.7 to 11.8). Patients were electively admitted to hospital for 2.0 (0.1) days in the standard care group and 3.1 (0.9) days in the BPAP group. No significant difference was found on 6-minute walk distance test.
Köhnlein, 2014^37^ RCT | COPD | | 2) Standard care | 12 months
De Backer, 2011^19^ RCT | COPD | Inclusion: COPD (FEV1<50%, FEV1/FVC <70%), AECOPD requiring hospitalization, PaCO2 >45 mmHg, stopped smoking; Exclusion: home NIPPV prior to admission, invasive ventilation, asthma, restrictive lung disease, malignancy, HF, OSA. | 1) BPAP NOS | At least 6 months | The 6-minute walk distance increased significantly in the BPAP group (232 ± 151 m to 282 ± 146 m, p = 0.01), while there was no change in the control group (408 ± 34 m to 401 ± 78 m, p = 0.09). No significant difference was found between the groups.
De Backer, 2011^19^ RCT | COPD | | 2) Standard care | At least 6 months
Funk, 2010^27^ RCT | COPD | Inclusion: COPD; AECOPD requiring NIPPV or invasive ventilation; chronic nocturnal NIPPV use at home for ≥ 6 months; clinically stable, PaCO2 > 45 mmHg immediately after awakening from night without NIPPV; Exclusion: Severe psychiatric disorder likely to impair NIPPV compliance, other severe pulmonary diseases not COPD, other severe non-pulmonary diseases limiting prognosis, noncompliance to NIPPV, women of childbearing age, evidence of sleep apnea. | 1) BPAP NOS for 6 months | Longest duration: 12 months | Patients who received BPAP more than 9 months had significantly increases (43%) in the 6-minute walk distance test while the group with 6-month treatment decreased by 11% (p =0.04). No significant difference was found on quality of life (the Saint George’s Respiratory Questionnaire).
Funk, 2010^27^ RCT | COPD | | 2) BPAP NOS for more than 6 months | Longest duration: 12 months
Dreher, 2010^21^ RCT | COPD | Inclusion: COPD (Gold stage IV); daytime PaCO2 > 45 mmHg; nocturnal PaCO2 > 50 mmHg; Exclusion: Acute RF, invasive ventilation via tracheostomy, weaned from invasive ventilation, intubated during prior 3 months, other ventilatory support prior to study. | 1) HMV (pressure controlled ventilation) (time period 1) | 1.5 months | Treatment compliance was higher in the HMV (pressure controlled ventilation) group than the HMV (pressure support ventilation) group (10.8 hours per day vs. 7.7 hours per day, p=0.02). The HMV (pressure controlled ventilation) group had higher Borg dyspnea scale after 6-minute walk distance test (2.4, 95% CI: 0.4 to 4.3, p=0.03). There were no significant difference on quality of life (Severe Respiratory Insufficiency Questionnaire Summary Score), and 6-minute walk distance test.
Dreher, 2010^21^ RCT | COPD | | 2) HMV (pressure support ventilation)(time period 1) | 1.5 months
Dreher, 2010^21^ RCT | COPD | | 2) Pulmonary rehabilitation alone | 1.5 months
Tsolaki, 2008^65^ Observational | COPD | Inclusion: COPD (FEV1 <50%, FEV/FVC <70%); smoking >20 pack years; Age≤75 years; PaO2 < 60 mmHg (room air); PaCO2 >50 mmHg (room air); Exclusion: Significant comorbidities (OSA, OHS, RF from disease other than COPD), important concomitant chronic systemic disorders, poor ventilator compliance, apnea-hypopnea index ≥10 episodes/hour. | 1) BPAP ST | 12 months | Compared to standard care, the BPAP group was found to have significantly better outcomes on Medical Research Council dyspnea score, Epworth Sleepiness Scale, SF-36 Physical Component Summary score, and SF-36 Mental Component Summary score. Patients in the BPAP group spent significantly less days in hospital (6.6 days vs. 16.0 days, p=0.02).; There was no significant difference on number of exacerbations, hospitalization due to exacerbations, endotracheal intubation, or mortality.
Tsolaki, 2008^65^ Observational | COPD | | 2) Standard care | 12 months
Chiang, 2003^13^ RCT | COPD, other | Inclusion: COPD or asthma or bronchiectasis; hospital readmission due to respiratory cause; daytime sleepiness or morning headache; PaCO2 > 50 mmHg (daytime rest); SpO2 < 88% for more than 5 consecutive minutes while on usual oxygen during polysomnography; Exclusion: Unable to tolerate nocturnal nasal positive pressure ventilation, OSA, unable to perform 6-minute walk distance test due to other disease. | 1) BPAP NOS | 6 months | Compared to the standard care group, the BPAP group had significantly better outcomes on 6-minute walk distance test group (101.2 meters vs. −33.8 meters, p<0.05), number of hospitalization, and total hospital stay. No significant difference was found on resting Borg score and Borg score at end of 6-minute walk distance test.
Chiang, 2003^13^ RCT | COPD, other | | 2) Standard care | 6 months
Gay, 1996^31^ RCT | COPD | Inclusion: COPD (FEV1 < 40%); PaCO2 >45 mmHg (daytime, rest); Age<80 years, BMI≤30; Exclusion: activated for lung transplantation, active psychiatric disease that necessitated sedative or hypnotic meds, current use of nocturnal ventilation or continuous PAP, major illness likely to preclude completion of prolonged trial. | 1) BPAP ST | 3 months | No difference was found on 6-minute walk distance test, total sleep time, sleep efficiency, REM sleep, and multiple sleep latency tests.
Gay, 1996^31^ RCT | COPD | | 2) Sham BPAP ST/no device | 3 months | No difference was found on 6-minute walk distance test, total sleep time, sleep efficiency, REM sleep, and multiple sleep latency tests.
Gad, 2014^28^ Observational | COPD | Inclusion: COPD (FEV1 < 50%, FEV1/FVC <70%); clinically stable (no exacerbation in prior 4 weeks); PaCO2 ≥ 50 mmHg (daytime); Exclusion: invasive MV, OSA, cardiac disease limiting exercise tolerance, NMDs, orthopedic impairment of shoulder girdle. | 1) BPAP ST + Exercise program | 3 months | After 3 month, compared to the exercise group, the BPAP group had significantly better outcomes on quality of life (COPD Assessment Test, 20.2 vs. 23, p=0.01).
Gad, 2014^28^ Observational | COPD | | 2) Exercise program | 3 months | After 3 month, compared to the exercise group, the BPAP group had significantly better outcomes on quality of life (COPD Assessment Test, 20.2 vs. 23, p=0.01).
Sin, 2007^62^ RCT | COPD | Inclusion: COPD (FEV1/FVC < 70%, post-bronchodilator FEV1 <70%, smoking ≥10 pack years); age≥40 years; Exclusion: Comorbidities making survival <6mo. Unlikely, clinical history of left ventricular HF, apnea-hypopnea index >20. | 1) BPAP NOS + Standard care | 3 months | After 3 months, the changes in 6-minute walk distance test was significant in the BPAP group (30 meters, 95% CI, 2 to 57) while not significant in sham group (4 meters; 95% CI, - 38 to 47 m). However, the difference between the groups was not significant.
Sin, 2007^62^ RCT | COPD | | 2) Sham BPAP/no device | 3 months
Heinemann, 2011^34^ Observational | COPD | Inclusion: COPD; prolonged weaning from invasive mechanical ventilation Exclusion: intubated due to cardiogenic edema or cardiopulmonary resuscitation | 1) HMV pressure controlled ventilation | 12 months | Patients received HMV were more likely to survive after 1-year followup than patients received standard care (HR=3.63, 95% CI: 1.23 to 10.75, p=0.02).
Heinemann, 2011^34^ Observational | COPD | Inclusion: COPD; prolonged weaning from invasive mechanical ventilation Exclusion: intubated due to cardiogenic edema or cardiopulmonary resuscitation | 2) No device | 12 months | Patients received HMV were more likely to survive after 1-year followup than patients received standard care (HR=3.63, 95% CI: 1.23 to 10.75, p=0.02).
Budweiser, 2007^8^ Observational | COPD | Inclusion: severe COPD (Global Initiative of Chronic Obstructive Lung Disease (GOLD) IV, FEV1/VC < 70% and FEV1< 50% predicted, PaCO2≥50 mmHg after optimization of therapy or treatment of exacerbation), age<80 years Exclusion: prior diagnosis of a malignancy within 5 years, underwent intubation or tracheostomy prior to BPAP ST | 1) BPAP ST | 48 months | The BPAP ST group (mean followup: 19.8 months) had significantly lower mortality than those in the standard care group (mean followup: 12.9 months) (HR=0.48; 95% CI: 0.24 to 0.93, p<0.05).
Budweiser, 2007^8^ Observational | COPD | | 2) Standard care/no device | 48 months | The BPAP ST group (mean followup: 19.8 months) had significantly lower mortality than those in the standard care group (mean followup: 12.9 months) (HR=0.48; 95% CI: 0.24 to 0.93, p<0.05).
Clini, 2002^16^ RCT | COPD | Inclusion: severe COPD (he American Thoracic Society criteria), CVF, stable clinical condition (arterial pH>7.35, free from exacerbation in the 4 weeks), age≤75 years, LTOT at least 6 months, MRC dyspnea score≥2, FEV1<1.5 L, FEV1/FVC<60%, total lung capacity ≥90% predicted, PaCO2>6.6 kPa, PaO2<7.8 kPa Exclusion: 15% increase in FEV1 after inhaled salbutamol (200 mg), pH≤7.34, active smoking, history of obstructive sleep apnea syndrome, therapy with systemic steroids, important concomitant chronic systemic diseases (e.g. significant fibrothorax, bronchiectasis, cystic fibrosis), concomitant NPPV, other home care program apart from LTOT | 1) BPAP ST plus LTOT | 24 months | Compared to the LTOT group, the BPAP ST plus LTOT group had significantly better outcomes on dyspnea (measured by the MRC scale, −0.60, 95% CI: −1.05 to −0.15), and sleep quality (measured by a semi-qualitative multipoint scale with a range 1 (best) to 4 (worst), −0.31, 95% CI: −1.0 to −0.1). There was no significantly difference on mortality (17% in both groups), exercise tolerance (measured by 6-minute walking distance test), quality of life (measured by Saint George’s Respiratory Questionnaire, p=0.55), hospital admissions (0.9 per patient per year vs. 1.4 per patient per year), length of hospitalization, and ICU admissions (0.2 per patient per year vs. 0.4 per patient per year).
Clini, 2002^16^ RCT | COPD | | 2) LTOT | 24 months
Struik, 2014^64^ RCT | COPD | Inclusion: Severe COPD (GOLD stage 3 and 4), >48 hours independence from ventilatory support (invasive or non-invasive) for ARF, prolonged hypercapnia(PaCO 2 >6.0 kPa) during daytime at rest without oxygen or ventilatory support | 1) BPAP ST | 12 months | There was no significant difference between the BPAP ST group and the Standard Care group on mortality (30 vs. 29), survival time (mean: 299 days vs. 291 days, p=0.99), number of hospital admissions (1.0 per person per year vs. 1.0 per person per year), number of patients with hospital readmissions due to respiratory causes (56% vs. 57%), length of hospitalization (7.0 days vs. 3.5 days, p=0.09), annual number of exacerbations at home (median: 1.0 vs. 2.0, p=0.26), quality of life (measured by Chronic Respiratory Questionnaire, 0.01, 95% CI: −0.4 to 0.4), dyspnea scale (measured by MRC dyspnea, −0.05, 95% CI: −0.6 to 0.5), and activity of daily living (measured by Groninger Activity Restriction Scale, 0.4, 95% CI: −2.3 to 3.0).
Struik, 2014^64^ RCT | COPD | | 2) Standard care | 12 months
Durao, 2018^25^ Observational | COPD | Inclusion: COPD NOS; Exclusion: No clinical assessment in prior 6 months, OSA with a history of noncompliance with CPAP | 1) HMV/BPAP mix started in AECOPD | >1 year | There were no difference on number of hospital admission for respiratory causes (changes before and after NIPPV per year: −0.6 vs. −0.3, p=0.46) and length of hospital stay for respiratory causes (changes before and after NIPPV per year: −9.8 days vs. −1.7 days, p=0.09).
Durao, 2018^25^ Observational | COPD | Inclusion: COPD NOS; Exclusion: No clinical assessment in prior 6 months, OSA with a history of noncompliance with CPAP | 2) HMV/BPAP mix started in stable disease | >1 year
Duiverman, 2017^24^ RCT | COPD | Inclusion: COPD (GOLD III or IV), ≥ 2 AECOPD with acute hypercapnic respiratory failure (pH<7.35) per year, daytime Inclusion: PaCO2 ≥6.7 kPa (50 mmHg) or nocturnal PaCO2 ≥7.3 kPa (55 mmHg) or nighttime rise in PtCO2 ≥1.3 kPa (10 mmHg), stable (no AECOPD in prior 4 weeks, pH>7.35). | 1) HMV/BPAP mix (pressure controlled ventilation) (high intensity) | 1.5 months | There was no statistical difference between two groups on quality of life (the COPD assessment test, WMD: 2.30, 95% CI: −2.35 to 6.95).
Duiverman, 2017^24^ RCT | COPD | | 2) HMV (pressure controlled ventilation) (low intensity) | | There was no statistical difference between two groups on quality of life (the COPD assessment test, WMD: 2.30, 95% CI: −2.35 to 6.95).
Oscroft, 2010^49^ RCT | COPD | COPD, FEV1<50%, FEV1/FVC<70%, TLC>80%, >20 pack year smoking history, pH 7.35-7.45, PaCO2>7.5 kPa or PtcCo2>9kPa, treated with NIPPV for at least 3 months with compliance at least 4 hours/day, clinical stability (no increased breathlessness, cough or sputum in the prior 4 weeks, no increase in PaCO2 and no decrease in FEV1 since study initiation) | 1) BPAP (pressure controlled ventilation) | 6 months | There was no significant difference between the two groups on quality of life (St. Georges Respiratory Questionnaire, p=0.10).
Oscroft, 2010^49^ RCT | COPD | | 2) No device | 6 months | There was no significant difference between the two groups on quality of life (St. Georges Respiratory Questionnaire, p=0.10).

Note: ± denotes standard deviation.

AECOPD: acute exacerbation of chronic obstructive pulmonary disease, AHRF: acute hypoxemic respiratory failure, ATS: American Thoracic Society, BPAP: Bilevel Positive Airway Pressure, CI: confidence interval, COPD; chronic obstructive pulmonary disease, CPAP: Continuous Positive Airway Pressure, CRF: Chronic Respiratory Failure, BMI: Body Mass Index, FEV1: Forced expiratory volume in one second, FVC: Forced vital capacity, HF: heart failure, HMV: Home Mechanical Ventilation, HR: hazard ratio, ICU: Intensive Care Unit, IVAPS: intelligent volume assured pressure support, kPa: kilopascal, LTOT: long term oxygen therapy, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive positive pressure ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OHS: Obesity hypoventilation syndrome, OR: odds ratio, OSA: Obstructive sleep apnea, PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, PAP: positive airway pressure, pH: potential of hydrogen, PSV: Pressure support ventilation, PtcCO2: transcutaneous pressure of carbon dioxide, RCT: randomized controlled trial, REM: rapid eye movement, RF: Respiratory Failure, S: spontaneous mode, SaO2: arterial blood oxygen saturation, SF-36: Medical Outcomes Study Questionnaire Short Form, SpO2: peripheral capillary oxygen saturation, ST: spontaneous/timed breath mode, TLC: total lung capacity, WMD: weighted mean difference

Table F.13 Thoracic Restrictive Disorders – Effectiveness of home devices

Author, Year, Study Design | Disease | Inclusion/Exclusio n Criteria | Device And Settings Used (Group) (add n per arm) | Duration Of Device Use In Home Setting | Conclusion
Buyse, 2003^9^ Observational | TRD | Inclusion: Kyphoscoliosis with respiratory insufficiency who started LTOT and/or NIPPV. | 1) HMV (volume cycled or pressure cycled) + oxygen | 10 months | Survival rate was significantly higher in patients treated with HMV plus long-term oxygen than patients with long-term oxygen alone (p<0.05)
Buyse, 2003^9^ Observational | TRD | Inclusion: Kyphoscoliosis with respiratory insufficiency who started LTOT and/or NIPPV. | 2) Oxygen alone | 10 months | Survival rate was significantly higher in patients treated with HMV plus long-term oxygen than patients with long-term oxygen alone (p<0.05)
Schonhofer, 2001^61^ Observational | TRD | Inclusion: TRD (post-TB or scoliosis); PaCO2 45-55 mmHg; stable PaCO2 compared to baseline; stable disease (no hospital admission 1 month prior); Exclusion: Rapidly progressive NMD, OHS, COPD, acute RF, severe acidosis. | 1) Mixed: HMV (volume assist control ventilation) with change to BPAP ST if not tolerated | 3 months | HMV: significant improvements before and after 3-month treatment in inspiratory threshold loading test (278%), cycle ergometer test (176%), and shuttle walking test (32%). Standard care: no significant changes before and after 3month treatment.
Schonhofer, 2001^61^ Observational | TRD | | 2) Standard care without HMV/BPAP device | 3 months

COPD: chronic obstructive pulmonary disease, HMV: Home Mechanical Ventilation, LTOT: long term oxygen therapy, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive Positive Pressure Ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OHS: obesity hypoventilation syndrome, PaCO2: partial pressure of arterial carbon dioxide, RF: Respiratory Failure, TB: tuberculosis, TRD: thoracic restrictive disorder

Table F.14 Neuromuscular Disorder – Effectiveness of Home Devices

Author, Year, Study Design | Disease | Inclusion/Exclusio n Criteria | Device And Settings Used (Group) | Duration Of Device Use In Home Setting | Conclusion
Sanjuan-López, 2014^60^ Observational | NMD | Inclusion: ALS; hospital admission; chronic RF by pulmonologist; Exclusion: Neuromuscular processes other than ALS, treatment in social welfare palliative center. | 1) HMV (pressure support ventilation mode or BPAP ST mode) started after outpatient pulmonary evaluation | 23.3 months (95% CI, 16.7–28.8) | Patients received HMV after pulmonary evaluation have longer length of survival than those without pulmonary evaluation (mean survival: 12.3 months vs. 2.8 months, p<0.004).
Sanjuan-López, 2014^60^ Observational | NMD | Inclusion: ALS; hospital admission; chronic RF by pulmonologist; Exclusion: Neuromuscular processes other than ALS, treatment in social welfare palliative center. | 2) HMV (pressure support ventilation mode or BPAP ST mode) started in an emergency situation without prior outpatient pulmonary evaluation | 26.7 months | Patients received HMV after pulmonary evaluation have longer length of survival than those without pulmonary evaluation (mean survival: 12.3 months vs. 2.8 months, p<0.004).
Pinto, 2010^54^ Observational | NMD | Inclusion: ALS; home BPAP use; FVC ≥75%; PaO2 ≥80 mmHg; PaCO2 ≤ 45 mmHg; age 18-75 years; Exclusion: Gastrostomy, cognitive impairment, other significant disorders. | 1) BPAP ST + Weekly telemonitoring + Standard care | 36 months | The BPAP ST + weekly telemonitoring group had significantly lower number of office visits (IRR: 0.34, 95% CI: 0.29 to 0.38); ER visits (IRR: 0.19; 95% CI: 0.10 to 0.37); hospital admission (IRR: 0.17; 95% CI: 0.07 to 0.41). There was no significant difference on mortality (OR= 1.00; 95% CI: 0.24 to 4.18) or median survival time (from BPAP adoption to death) (865 days vs. 334 days, p=0.13)
Pinto, 2010^54^ Observational | NMD | Inclusion: ALS; home BPAP use; FVC ≥75%; PaO2 ≥80 mmHg; PaCO2 ≤ 45 mmHg; age 18-75 years; Exclusion: Gastrostomy, cognitive impairment, other significant disorders. | 2) BPAP ST + Standard care | 36 months
Gonzalez-Bermejo, 2013^32^ Observational | NMD | Inclusion: ALS on home BPAP with 4 hour/night minimal adherence; Exclusion: Use of other ventilator types, without integrated SpO2 monitoring. | 1) BPAP ST “correctly ventilated patients” | 12 months | The “correctly ventilated” patients had significantly lower mortality than those “insufficiently ventilated” patients (OR= 0.25; 95% CI: 0.10 to 0.64).
Gonzalez-Bermejo, 2013^32^ Observational | NMD | Inclusion: ALS on home BPAP with 4 hour/night minimal adherence; Exclusion: Use of other ventilator types, without integrated SpO2 monitoring. | 2) BPAP ST “insufficiently ventilated patients” | 12 months | The “correctly ventilated” patients had significantly lower mortality than those “insufficiently ventilated” patients (OR= 0.25; 95% CI: 0.10 to 0.64).
Sancho, 2014^58^ Observational | NMD | Inclusion: ALS; symptoms (fatigue, dyspnea, orthopnea, morning headache) plus one of the following 1) PaCO2 >45 mmHg or 2) FVC <50% or 3) MIP <60 cm H2O or 4) SaO2 < 88% for ≥ 5 consecutive minutes by nocturnal oximetry; Exclusion: Presence of previous pulmonary/airway disease, rapidly progressing disease w/ survival expectancy <1 month, severe frontotemporal dementia, NIPPV tolerance <4 consecutive hour/night. | 1) HMV (volume assist control ventilation) | 15 months | No significant difference was found on length of survival (median 15.00 months (95% CI: 7.48 to 22.41) vs. median 15.00 months (95% CI; 95% CI 10.25 to 19.75), p=0.53)
Sancho, 2014^58^ Observational | NMD | | 2) BPAP ST | 15 months | No significant difference was found on length of survival (median 15.00 months (95% CI: 7.48 to 22.41) vs. median 15.00 months (95% CI; 95% CI 10.25 to 19.75), p=0.53)
Sivori, 2007^63^ Observational | NMD | Inclusion: ALS; symptomatic ventilatory impairment (dyspnea, morning headache, fatigue) plus 1) PaCo2 > 45 mmHg or 2) nocturnal oxygen saturation by pulse oximeter ≤ 88% for 5 continuous minutes or 3) MIP < 60 cmH2O or 4) FVC < 50%. | 1)BPAP, Riluzole | Longest Duration: 60 months | With a 30-month followup, 9 out of 11 patients died in the BPAP group; while 42 out of 42 patients in the no BPAP group (OR=0.04, 95% CI: 0.00 to 1.01, p=0.05).
Sivori, 2007^63^ Observational | NMD | | 2) BPAP NOS | Longest Duration: 60 months | With a 30-month followup, 9 out of 11 patients died in the BPAP group; while 42 out of 42 patients in the no BPAP group (OR=0.04, 95% CI: 0.00 to 1.01, p=0.05).
Sivori, 2007^63^ Observational | NMD | | 3) No BPAP, No Riluzole | Longest Duration: 60 months | With a 30-month followup, 9 out of 11 patients died in the BPAP group; while 42 out of 42 patients in the no BPAP group (OR=0.04, 95% CI: 0.00 to 1.01, p=0.05).
Coco, 2006^17^ Observational | NMD | Inclusion: ALS; symptomatic ventilatory impairment (dyspnea, morning headache, hypersomnolence, fatigue) plus 1) PaCO2 ≥ 45 mmHg or 2) nocturnal oxygen saturation by pulse oximeter ≤ 88% for 5 continuous minutes or 3) MIP < 60 cmH2O or 4) FVC < 50%; Exclusion: Primary lateral sclerosis, diagnosis other than ALS during followup. | 1) BPAP ST (use ≥ 4 hours/day) | Longest Duration: 30 months | The group with ≥4 hours/days use had significantly longer survival time from BPAP start to death (median: 18 months (interquartile range: 7 to 28) vs. 6 months (interquartile range: 3 to 12), p<0.001). No patient was lost to followup
Coco, 2006^17^ Observational | NMD | | 2) BPAP ST < 4 hours/day) | Longest Duration: 30 months
Bourke, 2006^7^ RCT | NMD | Inclusion: ALS; orthopnea with Pimax <60% or symptomatic daytime hypercapnia; Exclusion: Current or previous NIPPV use, significant co-morbidities, age>75 years, inability to complete quality of life assessment | 1) BPAP ST (full cohort) | 12 months | Patients with BPAP were also found to have better median survival length (216 days vs. 11 days, p=0.01) and quality of life measured by SF-36 mental components (168 vs. 99, p<0.01) and physical component (150 vs. 81, p<0.01).
Bourke, 2006^7^ RCT | NMD | | 2) no BPAP ST (full cohort) | 12 months
Pinto, 1995^53^ Observational | NMD | Inclusion: ALS; bulbar features; Exclusion: Tracheotomised, refusal of attempts to prolong survival. | 1) BPAP NOS | Longest Duration: 42 months | With a 3-year followup, patients treated with BPAP were founded to have significantly higher overall survival than patients with palliative management (p=0.004).
Pinto, 1995^53^ Observational | NMD | Inclusion: ALS; bulbar features; Exclusion: Tracheotomised, refusal of attempts to prolong survival. | 2) No BPAP NOS | Longest Duration: 42 months | With a 3-year followup, patients treated with BPAP were founded to have significantly higher overall survival than patients with palliative management (p=0.004).
Vitacca, 2017^68^ Observational | NMD | Inclusion: ALS NOS admitted to hospital, NIPPV use; Exclusion: dementia confirmed by Mini-Mental State Examination score <20, refusal of NIPPV | 1) HMV/BPAP mix started in FVC≥ 80% (early) | 36 months | The patients started in FVC≥ 80% (early) were found to have significantly longer survival time (31.33 months vs. 27.51 months, p=0.01) and lower mortality (HR: 0.46, 95% CI: 0.29 to 0.74; p=0.001) than the patients started in FVC <80% (late).
Vitacca, 2017^68^ Observational | NMD | Inclusion: ALS NOS admitted to hospital, NIPPV use; Exclusion: dementia confirmed by Mini-Mental State Examination score <20, refusal of NIPPV | 2) HMV/BPAP mix started in FVC <80% (late)
Sancho, 2018^59^ Observational | NMD | Inclusion: ALS (Escorial criteria), hospital admission; Exclusion: lung disease, <1 year life expectancy, NIV use <4 consecutive hours/night, slow disease progression (>3 yrs), severe frontotemporal dementia | 1) HMV (volume assist control ventilation) | Longest Duration: 36 months | The HMV group had significantly longer survival time than the group not treated with any device (mean: 18.50 months vs. 3.00 months, p=0.001). The significant difference was also found in patients with no or moderate bulbar dysfunction (mean: 20.00 months vs. 3.00 months, p=0.0001) and in patients with severe bulbar dysfunction (mean: 13.00 months vs. 3.00 months, p=0.001).
Sancho, 2018^59^ Observational | NMD | | 2) No device
Bertella, 2017^3^ RCT | NMD | Inclusion: ALS (definite via El Esocrial Criteria), stable disease (no respiratory infection in prior 3 months); Exclusion: cognitive impairment, severe comorbidity, contraindications to NIV, distance from hospital >40 km. | 1) BPAP volume assured pressure support ventilation outpatient initiation | 3 months | There was no statistically significant difference on dyspnea (measured by VAS score), sleep quality (measured by VAS score). No adverse events were reported in both groups.
Bertella, 2017^3^ RCT | NMD | | 2) BPAP volume assured pressure support ventilation inpatient initiation | 3 months | There was no statistically significant difference on dyspnea (measured by VAS score), sleep quality (measured by VAS score). No adverse events were reported in both groups.
Aboussouan, 1997^1^ Observational | NMD | Inclusion: ALS via el Escorial criteria; dyspnea on exertion or PaCO2 ≥ 45 mmHg or orthopnea or FVC < 60% predicted. | 1) HMV/BPAP mix tolerant | Longest Duration: 25 months | The intolerant patients had significantly higher mortality than the tolerant patients (OR: 20.00, 95% CI: 2.19 to 182.44, p<0.01).
Aboussouan, 1997^1^ Observational | NMD | Inclusion: ALS via el Escorial criteria; dyspnea on exertion or PaCO2 ≥ 45 mmHg or orthopnea or FVC < 60% predicted. | 2) HMV/BPAP mix intolerant | Longest Duration: 25 months | The intolerant patients had significantly higher mortality than the tolerant patients (OR: 20.00, 95% CI: 2.19 to 182.44, p<0.01).
Farrero, 2005^26^ Observational | NMD | ALS NOS | 1) HMV/BPAP mix in pre-protocol group | Longest Duration:48 months | No significant difference on survival time was observed between the two groups (p=0.84).
Farrero, 2005^26^ Observational | NMD | ALS NOS | 2) HMV/BPAP mix in post-protocol group | Longest Duration:48 months | No significant difference on survival time was observed between the two groups (p=0.84).

ALS: amyotrophic lateral sclerosis, BPAP: Bilevel Positive Airway Pressure, CI: confidence interval, cmH2O: centimeters of water (pressure), CPAP: Continuous Positive Airway Pressure, BMI: Body Mass Index, FEV1: Forced expiratory volume in one second, FVC: Forced vital capacity, HMV: Home Mechanical Ventilation, HR: hazard ratio, IRR: incidence rate ratio, MIP: maximum inspiratory pressure, mmHg: millimeters of mercury (pressure), NIV: noninvasive ventilation, NIPPV: Noninvasive Positive Pressure Ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OR: odds ratio, PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, Pimax: maximal inspiratory mouth pressures, PSV: Pressure support ventilation, RCT: randomized controlled trial, RF: Respiratory Failure, SaO2: arterial blood oxygen saturation, SF-36: Medical Outcomes Study Questionnaire Short Form, SpO2: peripheral capillary oxygen saturation, ST: spontaneous/timed breath mode, VAS: visual analog scale

Table F.15 Obesity Hypoventilation Syndrome – Effectiveness of home devices

Author, Year, Study Design | Disease | Inclusion/Exclusio n Criteria | Device And Settings Used (Group) (add n per arm) | Duration Of Device Use In Home Setting | Conclusion
Howard, 2016^36^ RCT | OHS | Inclusion: OHS (BMI >30, daytime PaCO2 >45 mmHg); Exclusion: Other conditions contributing to hypoventilation. | 1) BPAP ST | 3 months | No significant difference was found between groups on Epworth Sleepiness Scale scores (p=0.86), SF-36 Physical Component (p=0.37), SF-36 mental Component (p=0.57), Severe Respiratory Insufficiency Questionnaire (p=0.54) and physical activities (sedentary time awake min/day, moderate-to-vigorous physical activity, steps/day).
Howard, 2016^36^ RCT | OHS | Inclusion: OHS (BMI >30, daytime PaCO2 >45 mmHg); Exclusion: Other conditions contributing to hypoventilation. | 2) CPAP | 3 months
Masa, 2015^40,^ ^41^ RCT | OHS | Inclusion: OHS (BMI ≥ 30; stable PaCO2 ≥ 45 mmHg; pH ≥ 7.35; no clinical worsening in prior 2 months); severe OSA (apnea-hypopnea index ≥30); correctly executed 30min CPAP/NIPPV treatment test; age 15-80 years; Exclusion: COPD (FEV1/FVC <70%), NMD, narcolepsy, restless legs syndrome, psychophysical, severe chronic debilitating illness, severe chronic nasal obstruction. | 1) HMV/BPAP mix (all with bilevel pressure with assured volume) + lifestyle modification | 2 months | The HMV/BPAP group and the CPAP group reported significantly better sleep quality measured by Epworth Sleepiness Scale than the lifestyle modification group. No significant difference between the HMV/BPAP and CPAP group. Patients treated by HMV/BPAP were found to have significant better outcomes on 6-minute walk distance test than CPAP (p=0.01). There was no difference between groups on quality of life and number of dropouts.
Masa, 2015^40,^ ^41^ RCT | OHS | | 2) CPAP + Lifestyle modification | 2 months
Masa, 2015^40,^ ^41^ RCT | OHS | | 3) Lifestyle modification | 2 months
Borel, 2011^6^, RCT | OHS | Inclusion: OHS (BMI >30; daytime PaCO2 ≥ 45 mmHg); age 20-75 years; Exclusion: Declined or presented any significant airway obstruction, scoliosis, cardiac failure, progressive NMD. | 1) BPAP ST | Longest Duration: 1 month | No significant difference were found on sleep quality measured by Epworth Sleepiness Scale (p=0.49).
Borel, 2011^6^, RCT | OHS | Inclusion: OHS (BMI >30; daytime PaCO2 ≥ 45 mmHg); age 20-75 years; Exclusion: Declined or presented any significant airway obstruction, scoliosis, cardiac failure, progressive NMD. | 2) Lifestyle counseling | Longest Duration: 1 month | No significant difference were found on sleep quality measured by Epworth Sleepiness Scale (p=0.49).
Murphy, 2012^45^, RCT | OHS | Inclusion: OHS (BMI>40, daytime chronic PaCO2 >6 kPa, pH >7.35), absence of other identifiable hypoventilation cause, FEV1/FVC >70%, FVC <70%; Exclusion: Inability to provide written consent. | 1) BPAP AVAPS | Longest Duration: 3 months | There was no statistically significant difference on quality of life (Severe Respiratory Insufficiency Questionnaire summary score, mean difference: 5, p=0.21), sleep quality (Epworth Sleepiness Score; 1, p=0.43).
Murphy, 2012^45^, RCT | OHS | Inclusion: OHS (BMI>40, daytime chronic PaCO2 >6 kPa, pH >7.35), absence of other identifiable hypoventilation cause, FEV1/FVC >70%, FVC <70%; Exclusion: Inability to provide written consent. | 2) BPAP ST | Longest Duration: 3 months
Piper, 2008^55^, RCT | OHS | Inclusion: OHS (BMI≥30, PaCO2 ≥ 45 mmHg (awake, stable), absence of another cause for hypercapnia, FEV1/FVC ≥ 70%); Exclusion: psychiatric illness, current home NIPPV use, PtcCO2 during REM ≥10mmHg, increase in afternoon to morning PaCO2 ≥10mmHg in patients with awake PaCO2 >55 mmHg. | 1) CPAP | Longest Duration: 3 months | No significant difference was found between the groups on Epworth Sleepiness Scale (p=0.59), SF-36 Physical Component (p=0.22), and SF-36 mental Component (p=0.28).
Piper, 2008^55^, RCT | OHS | | 2) BPAP S | Longest Duration: 3 months | No significant difference was found between the groups on Epworth Sleepiness Scale (p=0.59), SF-36 Physical Component (p=0.22), and SF-36 mental Component (p=0.28).
Masa, 2016, ^42^ RCT | OHS | Inclusion: OHS (BMI ≥ 30 kg/m2, no COPD, no NMD, no TRD, no narcooepsy, no restless leg syndrome), stable hypercapnic respiratory failure (daytime awake PaCO2 ≥ 45 mmHg, pH ≥ 7.35 and no clinical worsening in prior 2 months), ability to use NIPPV in 30 minute trial period; Exclusion: Psychophysical inability to complete questionnaires, severe chronic debilitating illness, severe chronic nasal obstruction, lack of informed consent. | 1) BPAP | 2 months | Patients in the BPAP group had significantly better improvements on Epworth Sleepiness Scale (p=0.02) and SF-36 Mental Component (p=0.04) than those in the lifestyle modification group. There was no signficaint difference on 6-minute walk distance test and SF-36 Physical Component.
Masa, 2016, ^42^ RCT | OHS | | 2) Lifestyle modification | 2 months
Perez de Llano, 2005^52^ Observational | OHS | Inclusion: OHS, BMI > 30, PaCO2 ≥ 50 mmHg, FEV1/FVc < 70%, absence of other respiratory disorder such as kyphoscoliosis or diaphragmatic paralysis | 1) HMV/BPAP mix | Longest duration: 105 months | Patients treated without any device had significantly higher mortality rate (OR= 14.88, 95% CI: 3.18 to 69.68, p= 0.001) than those treated by HMV/BPAP mix.
Perez de Llano, 2005^52^ Observational | OHS | Inclusion: OHS, BMI > 30, PaCO2 ≥ 50 mmHg, FEV1/FVc < 70%, absence of other respiratory disorder such as kyphoscoliosis or diaphragmatic paralysis | 2) no device | Longest duration: 105 months | Patients treated without any device had significantly higher mortality rate (OR= 14.88, 95% CI: 3.18 to 69.68, p= 0.001) than those treated by HMV/BPAP mix.
Priou, 2010^56^ Observational | OHS | Inclusions: BMI ≥ 30 kg/m 2 and daytime hypercapnia (PaCO2> 45 mm Hg) in the absence of any other cause of hypoventilation on the basis of clinical xamination, chest radiograph, and pulmonary function tests (eg, COPD [FEV 1 to vital capacity ratio, 70%]). | 1) BPAP in acute exacerbation | 50 months | There was no significant difference on mortality rate (OR= 1.27, 95% CI:0.49 to 3.27, p=0.63).
Priou, 2010^56^ Observational | OHS | | 2) BPAP in stable hypercapnia | 50 months | There was no significant difference on mortality rate (OR= 1.27, 95% CI:0.49 to 3.27, p=0.63).

AVAPS: average volume assured pressure support, BPAP: Bilevel Positive Airway Pressure, COPD: chronic obstructive pulmonary disease, CPAP: Continuous Positive Airway Pressure, BMI: Body Mass Index, FEV1: Forced expiratory volume in one second, FVC: Forced vital capacity, HMV: Home Mechanical Ventilation, kPa: kilopascal, LTOT: long term oxygen therapy, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive Positive Pressure Ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OHS: obesity hypoventilation syndrome, OSA: Obstructive sleep apnea, PaCO2: partial pressure of arterial carbon dioxide, pH: potential of hydrogen, RCT: randomized controlled trial, REM: Rapid eye movement, RF: Respiratory Failure, S: Spontaneous mode, SF-36: Medical Outcomes Study Questionnaire Short Form, ST: spontaneous/timed breath mode, PtcCO2: transcutaneous pressure of carbon dioxide

Table F.16 Other Respiratory Diseases – Effectiveness of home devices

Author, Year, Study Design | Disease | Inclusion/Exclusion Criteria | Device And Settings Used (Group) | Duration Of Device Use In Home Setting | Conclusion
Benhamou, 1997^2^, Observational | Other | Inclusion: Bronchiectasis; home nasal mask ventilation; LTOT. | 1) HMV (volume assist control ventilation) + Oxygen | Longest Duration: 89 months | No significant difference was found on survival between the HMV and oxygen therapy group and the oxygen therapy group (median 45 months vs. 48 months, p>0.05).
Benhamou, 1997^2^, Observational | Other | Inclusion: Bronchiectasis; home nasal mask ventilation; LTOT. | 2) Oxygen alone | Longest Duration: 89 months | No significant difference was found on survival between the HMV and oxygen therapy group and the oxygen therapy group (median 45 months vs. 48 months, p>0.05).

HMV: Home Mechanical Ventilation, LTOT: long term oxygen therapy

Table F.17 Mixed Diseases – Effectiveness of Home Devices

Author, Year, Study Design | Disease | Inclusion/Exclusio n Criteria | Device And Settings Used (Group) | Duration Of Device Use In Home Setting | Conclusion
Hazenberg, 2014^33^, RCT | NMD, TRD | Inclusion: NMD or thoracic cage disorder; PaCO2 >45 mmHg with respiratory symptoms; Exclusion: COPD, not mask naïve, acute RF, age < 18 years, invasive ventilation, nursing home resident. | 1) HMV started at home; pressure controlled ventilation with change to volume assist control ventilation if not tolerated | Longest Duration: 6 months | Compared to HMV started in the hospital, HMV started at home was not significantly better on mortality (OR=2.80, 95% CI: 0.51 to 15.43), withdrawals (OR= 1.03, 95% CI: 0.34 to 3.11), quality of life (Severe Respiratory Insufficiency, SF-36).
Hazenberg, 2014^33^, RCT | NMD, TRD | Inclusion: NMD or thoracic cage disorder; PaCO2 >45 mmHg with respiratory symptoms; Exclusion: COPD, not mask naïve, acute RF, age < 18 years, invasive ventilation, nursing home resident. | 2) HMV started in the hospital; pressure controlled ventilation) with change to volume assist control ventilation if not tolerated | Longest Duration: 6 months
Munoz, 2005^44^, Observational | NMD, TRD | Inclusion: Hospital admission with CHRF secondary to NMD (ALS excluded) or kyphoscoliosis or post TB sequelae; PaCO2 > 45 mmHg; HMV started in stable phase of disease; Exclusion: BiPAP users, ALS. | 1) HMV volume assist control ventilation | Longest Duration: 12 months | There was no statistically significant difference on mortality (OR= 0.91, 95% CI: 0.28 to 2.96, p=0.88), or number of hospital admissions (0.17 per patient in HMV volume assist/control mode vs. 0.04 per patient in HMV volume control mode, p=0.11).; Adverse events were similar between the two groups.
Munoz, 2005^44^, Observational | NMD, TRD | Inclusion: Hospital admission with CHRF secondary to NMD (ALS excluded) or kyphoscoliosis or post TB sequelae; PaCO2 > 45 mmHg; HMV started in stable phase of disease; Exclusion: BiPAP users, ALS. | 2) HMV volume control | Longest Duration: 3 months
Chiang, 2003^13^, RCT | COPD, other | Inclusion: COPD or asthma or bronchiectasis; hospital readmission due to respiratory cause; daytime sleepiness or morning headache; PaCO2 > 50 mmHg (daytime rest); SpO2 < 88% for more than 5 consecutive minutes while on usual oxygen during polysomnography; Exclusion: Unable to tolerate nocturnal nasal positive pressure ventilation, OSA, unable to perform 6-minute walk distance test due to other disease. | 1) BPAP NOS | 6 months | Patients in the BPAP group was found to have significantly better outcomes on 6-minute walk distance test (WMD: 99.80; 95% CI: 34.14 to 165.46; p<0.01), number of hospitalization per patient (WMD: −2.30: 95% CI: −3.36 to −1.24; p<0.001), and length of hospital stay (WMD: −37.70; 95% CI: −57.68 to −17.72; p<0.001). There was no statistical difference between the two groups on resting Borg score and Borg score at end of 6-minute walk distance test.
Chiang, 2003^13^, RCT | COPD, other | | 2) No BPAP NOS | 6 months

ALS: amyotrophic lateral sclerosis, BPAP: Bilevel Positive Airway Pressure, CHRF: chronic hypercapnic respiratory failure, CI: confidence interval, COPD: chronic obstructive pulmonary disease, mmHg: millimeters of mercury (pressure), NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OR: odds ratio, OSA: Obstructive sleep apnea, PaCO2: partial pressure of arterial carbon dioxide, RCT: randomized controlled trial, RF: Respiratory Failure, SF-36: Medical Outcomes Study Questionnaire Short Form, SpO2: peripheral capillary oxygen saturation, TB: tuberculosis, TRD: thoracic restrictive disorder, WMD: weighted mean difference

## KQ3 What are the equipment parameters that are used in each of the above groups?

Table F.18 COPD – Equipment parameters

Author, Year, Study Design | Device/mode | Model (Manufacturer; Location of Manufacturer) | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Vasquez, 2017^67^ Observational | BPAP NOS | NR | IPAP, EPAP | NR | NR
Vasquez, 2017^67^ Observational | CPAP NOS | NR | CPAP | NR | NR
Vasquez, 2017^67^ Observational | HMV NOS | NR | NR | NR | NR
Murphy, 2017^46^ RCT | BPAP ST | Harmony (Philips Respironics; USA); VPAP III STa (ResMed; Bella Vista, Australia) | IPAP, EPAP, rate | ≥ 6 hours nightly | −4.7 (2.5-5.6) hours/day (6 weeks); −7.6(3.6-8.4) hours/day (12 months).; -IPAP: 24 (22-26) cm H20; -EPAP: 4 (4-5) cmH20; -Rate: 14 (14-16) breaths/minute
Salturk, 2015^57^ Observational | BPAP ST | NR | IPAP, EPAP, rate | NR | −6.7 ± 1.9 hours/day; -IPAP: 24 ± 3 cm H20; -EPAP: 5.3 ± 0.7 cmH20
Oscroft, 2014^50^ RCT | BPAP volume assured pressure support ventilation | Intelligent volume assured pressure support (iVAPS) (ResMed; Bella Vista, Australia) | IPAP, EPAP, rate, target minute ventilation | NR | -Target minute ventilation 8.4 [5.7-9.8] L/minute; -EPAP: 4 (4-4) cmH20; -Rate: 15 (13.3-19.4) breaths/minute
Oscroft, 2014^50^ RCT | BPAP ST | NIPPY 3 (B and D Electromedical; Stratford, United Kingdom) | IPAP, EPAP, rate | NR | -IPAP: 28 (27.3-30) cmH20; -EPAP: 5 (5-5) cmH20; -Rate: 15.0 (15-15) breaths/minute
Paone, 2014^51^ Observational | BPAP ST | Synchrony (Philips Respironics; Andover, MA); Neftis (Linde; Munich, Germany) | IPAP, EPAP, rate | NR | -IPAP: 18.5 ± 2.66 cm H2O; -EPAP: 3.9 ± 1 cm H2O; -Rate: 12 breaths/minute
Galli, 2014^29^ Observational | BPAP NOS | NR | IPAP, EPAP | NR | -IPAP: 22.1 ± 6.2 cm H2O; -EPAP: 5.9 ± 1.8 cm H2O
Bhatt, 2013^4^ RCT | BPAP NOS | BiPAP Synchrony (Respironics Inc.; Murrysville, USA) | IPAP, EPAP | ≥ 6 hours daily for 6 months | -IPAP: 15 cm H2O; -EPAP: 5 cm H2O
Duiverman, 2011^22,^ ^23^ RCT | BPAP ST | BiPAP Synchrony (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | Followup #1:; -IPAP: 23 ± 4 cm H2O; -EPAP: 6 ± 2 cm H2O; -Rate: 18(3) breaths/minute; Followup #2:; −7.7 (5.8-8.5) hours/day; -IPAP: 20 ± 4 cm H2O; -EPAP: 6 ± 2 cm H2O; -Rate: 18 ± 3 breaths/minute
Oscroft, 2010^48^ Observational | BPAP ST | NIPPY l, 2 or 3 (B & D Electromedical; Stratford, United Kingdom) | IPAP, EPAP, rate | NR | -IPAP: 26 ± 3 cm H2O; -EPAP: 4 ± 1 cm H2O; -Short inspiratory (0.8- 1 s); -Long expiratory time (2.5-3.5 s).
Cheung, 2010^12^ RCT | CPAP | NR | CPAP | >8 hours nightly for 12 months | NR
Cheung, 2010^12^ RCT | BPAP ST | NR | IPAP, EPAP, rate | >8 hours nightly for 12 months | -7-9 hours/night; -IPAP: 14.8 ± 1.1 cm H2O; -EPAP: 5 ± 0 cm H2O
Hitzl, 2009^35^ Observational | HMV (pressure controlled ventilation) | NR | inspiratory pressure, PEEP, inspiratory time, rate | NR | -IPAP: 20.9 ± 4.0 cm H2O; -EPAP: 4.2 ± 1.9 cm H2O; -Rate: 19.1 ± 3.8 breaths/minute
McEvoy, 2009^43^ RCT | BPAP S | VPAP S mode (ResMed; Sydney, Australia) | IPAP, EPAP | NR | −4.5 (3.2) hours/day; -IPAP: 12.9 (12.5-13) cm H2O; -EPAP: 5.1 (4.8-5.3) cm H2O
Windisch, 2006^69^ Observational | HMV (pressure controlled ventilation) | PV401 (Breas Medical AB; Moelnlycke, Sweden) | inspiratory pressure, PEEP, inspiratory time, rate | NR | -IPAP: 31.0 ± 6.6 mbar; -Rate: 20.7 ± 2.1 breaths/minute; -Inspiratory time 1.0 ± 0.1 seconds
Casanova, 2000^10^ RCT | BPAP S | DP-90 (Taema; Paris, France) | IPAP, EPAP | NR | −6.2 hours/day (at 3 months); −5.9 hours/day (at 6 months); -IPAP: 12 ± 2 cm H2O
Garrod, 2000^30^ RCT | BPAP S | BiPAP ST 30 (Respironics Inc.; Murrysville, USA) | IPAP, EPAP | ≥ 8 hours daily | -IPAP: 16 (13-24) cm H2O; -EPAP: 4 (4-6) cm H2O
Clini, 1998^15^ Observational | BPAP ST | BiPAP (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | −7.4 ± 1.3 hours/day; -IPAP: 10-16 cm H2O; -EPAP: 2-4 cm H2O
Clini, 1996^14^ Observational | BPAP ST | BiPAP (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | NR
Zhou, 2017 RCT | BPAP ST | Flexo ST 30 NIV (Curative Co.; SuZhou, China) | IPAP, EPAP, rate | NR | −5.6 ± 1.4 hours/day; -IPAP: 17.8 ± 2.08 cm H2O; -EPAP: 4.2 ± 0.1 cm H2O
Marquez-Martin, 2014^38^ RCT | BPAP ST | BiPAP (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | -7 (6.5-9) hours nightly; -IPAP: 16 cm H2O (median) (both NIPPV groups); -EPAP: 4 cm H2O (median, both NIPPV groups)
Köhnlein, 2014^37^ RCT | BPAP ST | Models not reported. Manufacturers: ResMed (Martinsried, Germany), Weinmann (Hamburg, Germany, or Tyco Healthcare (Neubrug, Germany) | IPAP, EPAP, rate | ≥ 6 hours daily | -IPAP: 21.6 ± 4.7 cm H2O; -EPAP: 4.8 ± 1.6 cm H2O; -Rate: 16.1 ± 3.6 breaths/minute; -Ventilator use measured in 48 (47%) of patients. In these 48 patients, 65% exceeded the prescribed usage of ≥ 6 hours daily)
De Backer, 2011^19^ RCT | BPAP NOS | BiPAP Synchrony (Respironics Inc., Murrysville, USA) | IPAP, EPAP | > 5 hours daily | NR
Funk, 2010^27^ RCT | BPAP NOS | NR | IPAP, EPAP | NR | NR
Dreher, 2010^21^ RCT | HMV (pressure controlled ventilation) | Breas Vivo 40 (Breas Medical AB; Molnlycke, Sweden); Smart Air (Airox; Pau Cedex, France) | inspiratory pressure, PEEP, inspiratory time, rate, inspiratory flow trigger | Entire night while sleeping and during daytime naps. | -IPAP: 28.6 ± 1.9 cm H2O; -EPAP: 4.5 ± 0.7 cm H2O; -Rate: 17.5 ± 0.7 breaths/minute
Dreher, 2010^21^ RCT | HMV (pressure support ventilation) | Breas Vivo 40 (Breas Medical AB; Molnlycke, Sweden); Smart Air (Airox; Pau Cedex, France) | inspiratory pressure, PEEP, inspiratory flow trigger, expiratory flow trigger | Use the entire night while sleeping and during daytime naps. | -IPAP: 14.6 ± 0.8 cm H2O; -EPAP: 4 ± 0 cm H2O; -Rate: 8.0 ± 0 breaths/minute
Tsolaki, 2008^65^ Observational | BPAP ST | VPAP III ST (ResMed; Sydney, Australia) | IPAP, EPAP, rate | ≥ 5 hours daily | -9 ± 2.2 hours/day; -IPAP: 15.3 ± 2 cm H2O; -EPAP: 5.4 ± 0.7 (4-8) cm H2O
Gay, 1996^31^ RCT | BPAP ST | BiPAP (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | −5.1 ± 3.8 hours/day
Gad, 2014^28^ Observational | BPAP ST | NR | IPAP, EPAP, rate | NR | -IPAP: 15.5 ± 4.2 cm H2O; -EPAP: 4.0 ± 0 cm H2O; -9 ± 2 hours/day
Sin, 2007^62^ RCT | BPAP NOS | VPAP II (ResMed; Sydney, Australia) | IPAP, EPAP | NR | NR
Heinemann, 2011^34^ Observational | BPAP (pressure controlled ventilation) | NR | IPAP, EPAP, rate, inspiratory time | NR | -IPAP: 22.7 ± 4.3 mbar; -EPAP: 5.0 ± 1.3 mbar; -Rate: 16.8 ± 3.0 breaths/minute
Budweiser, 2007^8^ Observational | BPAP (pressure controlled ventilation) | Twin Air (Airox Inc.; Pau, France); Smart Air (Airox Inc.; Pau, France); BiPAP Synchrony (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate, inspiratory time | NR | −6.5 ± 2.5 hours/day; -IPAP: 21.0 ± 4.0 cm H2O; -EPAP: 4.5 ± 1.4 cm H2O; -Rate: 17.3 ± 2.5 breaths/minute
Clini, 2002^16^ RCT | BPAP ST | BiPAP ST 30 (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | -9 ± 2 hours/day; -IPAP: 14 ± 3 cm H2O; -EPAP: 2 ± 1 cm H2O
Struik, 2014^64^ RCT | BPAP ST | BiPAP Synchrony (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | −6.3 ± 2.4 hours/day; -IPAP: 19.2 ± 3.4 cm H2O; -EPAP: 4.8 ± 1.0 cm H2O; -Rate: 15 ± 3 breaths/minute; -Inspiratory time 1.1 ± 0.3 s
Durao, 2018^25^ Observational | HMV/BPAP mix. HMV mode: pressure controlled ventilation. BPAP modes: ST and volume assured pressure support ventilation | VPAP ST S9 (Resmed); VPAP ST STA (Resmed); BIPAP PR1 (Philips Respironics); BiPAP A30 (Philips Respironics); BiPAP A40 (Philips Respironics); Trilogy 100 (Philips Respironics) | IPAP, EPAP, rate, inspiratory time, target tidal volume | NR | −8.7 ± 3.6 hours/day; -IPAP: 23.7 ± 5.3 cm H2O; -Rate: 15.2 ± 1.4 breaths/minute
Duiverman, 2017^24^ RCT | HMV/BPAP mix (pressure controlled ventilation) (high intensity) | Breas Vivo 50 (Breas Medical AB; Molnlycke, Sweden); Stellar 100; Resmed (Martinsried, Germany) | inspiratory pressure, PEEP, inspiratory time, rate, inspiratory flow trigger | | −4.6 (0.11-9.2) hours/day; -IPAP: 23.6 ± 3.1 cm H2O; -EPAP: 5.4 ± 0.9 cm H2O; -Rate: 15.4 ± 0.8 breaths/minute
Duiverman, 2017^24^ RCT | HMV/BPAP mix (pressure support ventilation) (low intensity) | Breas Vivo 50 (Breas Medical AB; Molnlycke, Sweden); Stellar 100; Resmed (Martinsried, Germany) | inspiratory pressure, PEEP, inspiratory flow trigger, expiratory flow trigger | | −4.2 (0.04-7.5) hours/day; -IPAP: 15.5 ± 1.1 cm H2O; -EPAP: 5.2 ± 0.6 cm H2O; -Rate: 11.6 ± 1.5 breaths/minute
Blankenburg, 2017^5^ Observational | HMV (pressure controlled ventilation or pressure support ventilation) | VS III; ResMed (Saime SA, France) | inspiratory pressure, PEEP, inspiratory time, rate, inspiratory flow trigger | 12 hours/day | −5.6 ± 4.4 hours/day; -Inspiratory pressure 22 ± 3.7 cm H2O; -PEEP: 2.3 ± 2.5 cm H2O; -Rate: 15.8 ± 3.3 breaths/minute
Oscroft, 2010^49^ Observational | BPAP (pressure controlled ventilation) | NIPPY 2; B and D Electromedical (Stratford, United Kingdom) | IPAP, EPAP, rate | At least 4 hours daily | −7.4 ± 1.7 hours/day; -IPAP: 30 ± 6 cm H2O; -EPAP: 4 ± 1 cm H2O; -Rate: 16 breaths/minute
Tsolaki, 2011^66^ Observational | BPAP ST | VPAP III ST (ResMed; Sydney, Australia) | IPAP, EPAP, rate | ≥ 4 hours daily | -IPAP: 15.4 ± 1.9 cm H2O; -EPAP: 5.4 ± 0.9 cm H2O

Note: ± denotes standard deviation. Equipment parameters not reported: mask type, supplemental oxygen, heat and moisture exchanger

BPAP: Bilevel Positive Airway Pressure, cmH2O: centimeters of water (pressure), COPD: Chronic obstructive pulmonary diseases, CPAP: Continuous Positive Airway Pressure, EPAP: Expiratory positive airway pressure, FDA: Food and Drug Administration, H2O: Hydrogen dioxide, HMV: Home Mechanical Ventilation, IPAP: inspiratory positive airway pressure, IVAPS: Intelligent volume assured pressure support, NOS: Not Otherwise Specified, NR: Not Reported, PEEP: positive end expiratory pressure. S: spontaneous mode, ST: Spontaneous/timed, USA: United States of America, VPAP: Variable positive airway pressure.

Table F.19 Thoracic Restrictive Disorders – Equipment parameters

Author, Year, Study Design | Device/mode | Model; Manufacturer (Location of manufacturer) | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Salturk, 2015^57^ Observational | BPAP ST | NR | IPAP, EPAP, rate | NR | −5.9 ± 1.8 hours/day; -IPAP: 22 ± 5 cm H20; -EPAP: 5.3 ± 0.6 cmH20
Hitzl, 2009^35^ Observational | HMV (pressure controlled ventilation) | NR | inspiratory pressure, PEEP, inspiratory time, rate | NR | -IPAP: 20.9 ± 4.0 cm H2O; -EPAP: 4.2 ± 1.9 cm H2O; -Rate: 19.1 ± 3.8 breaths/minute
Doménech-Clar, 2003^20^ Observational | BPAP NOS | DP-90 (Taema; Paris, France) | IPAP, EPAP | ≥7 hours/night | -mean 6 hours/night
Buyse, 2003^9^ Observational | HMV (volume cycled or pressure cycled) | Eole 3 (Saime; Savigny-Le-Temple, France); O’nyx (Nellcor Puritan Bennet; Villersles-Nancy, France) | NR | NR
Nauffal, 2002^47^ Observational | BPAP NOS | DP-90 (Taema; Paris, France) | IPAP, EPAP | NR | -mean 7 hours/night
Schonhofer, 2001^61^ Observational | Mixed: HMV (volume assist control ventilation) with change to BPAP ST if not tolerated | HMV: Drager EV 800 (Drager; Lubeck, Germany) or PLV 100 (Respironics; Murrysville, USA); BPAP ST: BP-T (Respironics Inc.; Murrysville, USA) | HMV: tidal volume, PEEP, rate; BPAP: IPAP, EPAP, rate | NR | NR
Masa, 2000^39^ Observational | HMV (volume cycled or pressure cycled) | Monal DCC (Taema; Paris, France).; If could not tolerate Monal DCC, then patients were switched to a Onyx Plus (Mallinckrodt SEFAM; Nancy, France). | NR | NR | −7.3 ± 0.7 hours/day
Tsolaki, 2011^66^ Observational | BPAP ST | VPAP III ST (ResMed; Sydney, Australia) | IPAP, EPAP, rate | ≥ 4 hours daily | -IPAP: 14.7 ± 2.4 cm H2O; -EPAP: 5.0 ± 1.1 cm H2O

Note: ± denotes standard deviation.

BPAP: Bilevel Positive Airway Pressure, cm: Centimeter, EPAP: Expiratory positive airway pressure, FDA: Food and Drug Administration, H2O: Hydrogen dioxide, HMV: Home Mechanical Ventilation, IPAP: Inspiratory positive airway pressure, NOS: Not Otherwise Specified, NR: Not reported, PEEP: positive end expiratory pressure, ST: Spontaneous/timed, TRD: Thoracic Restrictive Disorder, USA: United States of America.

Table F.20 Neuromuscular Disease – Equipment parameters

Author, Year, Study Design | Device/mode | Model and Manufacturer | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Sanjuan-López, 2014^60^ Observational | HMV (pressure support ventilation mode or BPAP ST mode) started after outpatient pulmonary evaluation versus HMV (pressure support ventilation mode or BPAP ST mode) started in an emergency situation without prior outpatient pulmonary evaluation | VS ultra and VS III (ResMed) | HMV device set to pressure support ventilation mode: Inspiratory pressure, PEEP, inspiratory flow trigger, expiratory flow trigger; HMV device set to BPAP ST mode: IPAP, EPAP, rate | NR | NR
Pinto, 2010^54^ Observational | BPAP ST + weekly telemonitoring | Goodknight 425ST bi-level device (Tyco Healthcare Group LP; California) | -IPAP, EPAP, rate; -FlowSens technology (allows the physician “to customize the inspiratory and expiratory settings for greater patient comfort and synchronicity”); -Telemonitoring (wireless telemetry to remotely monitor settings and change ventilator settings and to detect alarms. “The bidirectionality of the system allowed us not only to register compliance data but also to introduce modifications in parameter settings, thus permitting real time evaluation of its impact on ventilatory mechanics.” Patients were instructed to activate the system once a week or when difficulties arose. | ≥6 hours/day | NR
Pinto, 2010^54^ Observational | BPAP ST (no telemonitoring) | Goodknight 425ST bi-level device (Tyco Healthcare Group LP; California) | -IPAP, EPAP, rate; -FlowSens technology (allows the physician “to customize the inspiratory and expiratory settings for greater patient comfort and synchronicity”) | ≥6 hours/day | NR
Doménech-Clar, 2003^20^ Observational | BPAP NOS | DP-90 (Taema; Paris, France) | IPAP, EPAP | ≥7 hours/night | -Mean 6 hours/night
Nauffal, 2002^47^ Observational | BPAP NOS | DP-90 (Taema; Paris, France) | IPAP, EPAP | NR | -Mean 7 hours/night
Gonzalez-Bermejo, 2013^32^ Observational | BPAP ST | VPAP-III or VPAP-IV plus Reslink automatic ventilatory signal analysis (Resmed; Sydney, Australia) | IPAP, EPAP, rate | As long as possible at night and during daytime as needed | -IPAP: 13 ± 2 cm H2O; -EPAP: 5 ± 2 cm H2O; -Rate: 12 ± 1 breaths/minute
Sancho, 2014^58^ Observational | HMV, volume assist control ventilation | PV 501 (Breas Medical; Molndal, Sweden); Legendair (Airox; Pau, France) | Tidal volume, PEEP, rate | | -Tidal volume: 782.37 ± 107.57 ml; -Rate: 14.31 ± 1.14 breaths/minute
Sancho, 2014^58^ Observational | BPAP ST | VPAP-III or VPAP-IV plus Reslink automatic ventilatory signal analysis (Resmed; Sydney, Australia) | IPAP, EPAP, rate | | -IPAP: 12.01 ± 2.38 cm H2O; -EPAP: 4.43 ± 1.14 cm H2O; -Tidal volume: 417.84 ± 136.62 ml; -Rate: 11.66 ± 0.99 breaths/minute
Sivori, 2007^63^ Observational | BPAP NOS | NR | IPAP, EPAP | NR | NR
Coco, 2006^17^ Observational | BPAP ST | BiPAP (Respironics Inc.; Vitalaire, Italy) | IPAP, EPAP, rate | Use ≥ 4 or < 4 hours/day | NR
Bourke, 2006^7^ RCT | BPAP ST | VPAP STII (ResMed UK Ltd; Abingdon, United Kingdom) | IPAP, EPAP, rate | NR | -Mean 9.3 hours/day (good bulbar); -Mean 3.8 hours/day (poor bulbar); -Mean IPAP 15 cmH2O; -mean EPAP 4 cmH2O
Pinto, 1995^53^ Observational | BPAP NOS | NR | IPAP, EPAP | NR | NR
Vitacca, 2017^68^ Observational | HMV/BPAP mix using the following modes: ST, AVAPS, Bi-level, volume cycled, pressure controlled ventilation | NR | NR | ≥4 hours/day and ≥120hours/month | -IPAP: 15.33 ± 3.62 cm H2O; -EPAP: 5.34 ± 1.77 cm H2O; -Tidal volume: 7.06 ± 1.47 ml/kg; -Rate: 12.67 ± 1.46 breaths/minute
Sancho, 2017^59^ Observational | HMV (volume assist control ventilation) | Vivo 50; Breas Medical (Molndal, Sweden); Trilogy 100; Philips Respironics (Madrid, Spain) | Tidal volume, PEEP, rate | ≥4 hours/day | No/mild bulbar:; -Tidal volume: 790.09 ± 154.41 ml; -Rate: 14.5 ± 1.14 breaths/minute; Moderate/severe bulbar::; -Tidal volume: 717.14 ± 124.67 ml; -Rate: 14.80 ± 1.01 breaths/minute
Bertella, 2017^3^ RCT | BPAP volume assured pressure support ventilation | Trend II ST 30; Hoffrichter (Schwerin, Germany); BiPAP Synchrony II, Philips Respironics (Murrysville, PA, USA) | IPAP, EPAP, rate, target minute ventilation | ≥4 hours /day | Inpatient: 6.97 ± 1.05 hours/day; Outpatient: 7.68 ± 0.67 hours/day
Aboussouan, 1997,^1^ Observational | HMV/BPAP mix | HMV: PLV-100; Life Care Products (Lafayette, Colorado, USA); BPAP BiPAP; Respironics Inc. (Murrysville, Pennsylvania, USA) | NR | NR | NR
Farrero 2005,^26^ Observatrional | HMV/BPAP mix | HMV: PLV-100; Life Care Products or PV 501; BREAS Medical (Gothenburg, Sweden); BPAP: BiPAP; Respironics or VPAP ST II; Sullivan | NR | NR | NR
Tsolaki, 2011^66^ Observational | BPAP ST | VPAP III ST (ResMed; Sydney, Australia) | IPAP, EPAP, rate | ≥ 4 hours daily | -IPAP: 14.1 ± 2.1 cm H2O; -EPAP: 5.2 ± 0.4 cm H2O

Note: ± denotes standard deviation. Equipment parameters not reported: mask type, supplemental oxygen, heat and moisture exchanger

BPAP: Bilevel Positive Airway Pressure, cm: Centimeter, EPAP: Expiratory positive airway pressure, FDA: Food and Drug Administration, H2O: Hydrogen dioxide, HMV: Home Mechanical Ventilation, IPAP: Inspiratory positive airway pressure, NMD: Neuromuscular Disease, NOS: Not otherwise specified, NR: Not Reported, PEEP: positive end expiratory pressure, ST: Spontaneous/timed, USA: United States of America, VPAP: Variable positive airway pressure

Table F.21 Obesity Hypoventilation Syndrome – Equipment parameters

Author, Year, Study Design | Device/mode | Model and Manufacturer | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Howard, 2016^36^ RCT | BPAP ST | NR | IPAP, EPAP, rate | NR | −5.3 (2.63) hours/night; -IPAP: 19.3 ± 2.8 cm H20; -EPAP: 11.9 ± 2.3 cmH20; -Rate: 15.0 ± 2.7 breaths/minute
Howard, 2016^36^ RCT | CPAP | NR | CPAP | NR | −5.0(2.4) hours/night; -CPAP: 15.2 ± 2.8 cm H20
Salturk, 2015^57^ Observational | BPAP ST | NR | IPAP, EPAP, rate | NR | −6.4 ± 2.4 hours/day; -IPAP: 23 ± 3 cm H20; -EPAP: 5.8 ± 0.8 cmH20
Masa, 2000^39^ Observational | HMV (volume cycled or pressure cycled) | Monal DCC (Taema; Paris, France).; If could not tolerate Monal DCC, then patients were switched to a Onyx Plus (Mallinckrodt SEFAM; Nancy, France). | NR | NR | −7.2 ± 0.8 hours/day
Castillejo, 2014^11^ Observational | BPAP ST | Harmony BiPAP (Respironics; Louisville, USA) | IPAP, EPAP, rate | NR | −5.7 ± 1.3 hours/night
Masa, 2015^40,^ ^41^ RCT | Mixed: HMV and BPAP mix (all with bilevel pressure with assured volume) | Breas Vivo 40 (General Electric; England); BiPAP AVAPS (Phylips-Respironics; Netherlands); Trilogy 100 (Philips-Respironics; Netherlands); VS Ultra (ResMed; Australia); Monal T50 (Air Liquide; France); Puritian Bennett 560 (Puritan Bennett; USA) | IPAP, EPAP, rate, target minute ventilation | NR | -IPAP: at Initiation 20 ± 3.3 cm H2O; at 2 months 20 ± 3 cm H2O; -EPAP: at Initiation 7.7 ± 1.8 cm H2O; at 2 months 7.8 ± 1.8 cm H2O; -Rate: at Initiation 14 ± 3 breaths/minute; at 2 months 14 ± 3.1 breaths/minute
Masa, 2015^40,^ ^41^ RCT | CPAP | NR | CPAP | NR | -CPAP: at Initiation 11 ± 2.5 cm H2O; at 2 months 11 ± 2.6 cm H2O
Borel, 2011^6^ RCT | BPAP ST | GoodKnight-425ST (Covidien) | IPAP, EPAP, rate | NR | −5.6 ± 2.2 hours/night; -IPAP: 18 ± 3 cm H2O; -EPAP: 11 ± 2 cm H2O; -Rate: 13 ± 2 breaths/minute
Murphy, 2012^45^ RCT | BPAP volume assured pressure support ventilation | BiPAP synchrony (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate, target minute ventilation | NR | -EPAP: 9 ± 1 cm H2O; -Tidal volume: 657 ± 96 ml; -Rate: 14 ± 1 breaths/minute
Murphy, 2012^45^ RCT | BPAP ST | BiPAP synchrony (Respironics Inc.; Murrysville, USA) | IPAP, EPAP, rate | NR | -IPAP: 25 ± 3 cm H2O; -EPAP: 10 ± 2 cm H2O; -Rate: 14 ± 1 breaths/minute
Piper, 2008^55^ RCT | BPAP S | NR | IPAP, EPAP | NR | -IPAP: 16 ± 2 cm H2O; -EPAP: 10 ± 2 cm H2O
Piper, 2008^55^ RCT | CPAP | NR | CPAP | NR | NR
Blankenburg, 2017^5^ Observational | HMV (pressure controlled ventilation or pressure support ventilation) | VS III; ResMed (Saime SA, France) | Inspiratory pressure, PEEP, inspiratory time, rate, inspiratory flow trigger | 12 hours/day | −5.2 ± 3.2 hours/day; -Inspiratory pressure 22 ± 3.9 cm H2O; -PEEP: 5.3 ± 2.7 cm H2O; -Rate: 15.3 ± 2.9 breaths/minute
Masa 2016^42^ RCT | BPAP volume assured pressure support ventilation | NR | IPAP, EPAP, rate, target minute ventilation | NR | NR
Perez de Llano 2005^52^ Observational | HMV/BPAP mix | HMV:; Home 2; Airox (Pau, France); BPAP:; DP-90; Taema (Paris, France); PV-102; Breas (Gothenburg, Sweden) | HMV: volume cycled NOS | NR | NR
Priou, 2010^56^, Observational | BPAP | NR | NR | NR | NR
Tsolaki, 2011^66^ Observational | BPAP ST | VPAP III ST (ResMed; Sydney, Australia) | IPAP, EPAP, rate | ≥ 4 hours daily | -IPAP: 16.3 ± 2.4 cm H2O; -EPAP: 6.1 ± 1.0 cm H2O

Note: ± denotes standard deviation.

BPAP: Bilevel Positive Airway Pressure, cm: Centimeter, CPAP: Continuous Positive Airway Pressure, EPAP: Expiratory positive airway pressure, FDA: Food and Drug Administration, H2O: Hydrogen dioxide, HMV: Home Mechanical Ventilation, IPAP: Inspiratory Positive Airway Pressure, NR: Not reported, OHS: Obesity hypoventilation syndrome, PEEP: positive end expiratory pressure, S: spontaneous mode, ST: Spontaneous/timed mode, USA: United States of America.

Table F.22 Other Respiratory Diseases – Equipment parameters

Author, Year, Study Design | Device/mode | Model and Manufacturer | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Salturk, 2015^57^ Observational | BPAP ST | NR | IPAP, EPAP, rate | NR | −5.8 ± 1.4 hours/day; -IPAP: 21 ± 5 cm H20; -EPAP: 5.5 ± 0.7 cmH20
Benhamou, 1997^2^ Observational | HMV (volume assist control ventilation) | Monnal D (Taema; Antony, France); Eole 3 (Saime; Savigny-Le-Temple, France) | tidal volume, PEEP, rate | NR | NR

Note: ± denotes standard deviation.

BPAP: Bilevel Positive Airway Pressure, cm: Centimeter, EPAP: Expiratory positive airway pressure, FDA: Food and Drug Administration, H2O: Hydrogen dioxide, HMV: Home Mechanical Ventilation, IPAP: Inspiratory Positive Airway Pressure, NR: Not reported, PEEP: positive end expiratory pressure, ST: Spontaneous/timed mode

Table F.23 Mixed Diseases – Equipment parameters

Author, Year, Study Design | Diseases | Device/mode | Model and Manufacturer | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Hazenberg, 2014^33^ RCT | NMD, TRD | HMV (pressure controlled ventilation) with change to HMV (volume assist control ventilation) if not tolerated | Elisee 150; (ResMed; Paris, France); (FDA approved) | HMV (pressure controlled ventilation): inspiratory pressure, PEEP, rate, inspiratory time; HMV (volume assist control ventilation): tidal volume, PEEP, rate | ≥ 6 hours/night | -IPAP: 10 cm H2O (pressure mode); -EPAP: 4 cm H2O (pressure mode); -Tidal volume: 8-10 ml/kg (pressure mode)
Crespo, 2009^18^ Observational | COPD, TRD, NMD, OHS, Other | HMV (pressure or volume controlled NOS) | NR | NR | NR | [underlined: Age ≥ 75 years old]; -IPAP: 14-20 cm H20; -EPAP: 3-8 cmH20; -Tidal volume: 500-800 ml; -Rate: 16- 22 breaths/minute; [underlined: Age 65-74 years old]; -IPAP: 14-24 cm H20; -EPAP: 14-20 cmH20; -Tidal volume: 400-800 ml; -Rate: 14- 22 breaths/minute; [underlined: Age <65 years old]; -IPAP: 14-30 cm H20; -EPAP: 3-8 cmH20; -Tidal volume: 400-1000 ml; -Rate: 12- 24 breaths/minute
Munoz, 2005^44^ Observational | NMD, TRD | HMV (volume assist control ventilation) | NR | tidal volume, PEEP, rate | NR | -Tidal volume: 9.5 ± 0.7 ml/kg; -Rate: 16.8 ± 2.7 breaths/minute
Munoz, 2005^44^ Observational | NMD, TRD | HMV (volume control) | NR | tidal volume, PEEP, rate | NR | -Tidal volume: 8.61 ± 1.6 ml/kg; -Rate: 16.7 ± 2.7 breaths/minute
Chiang, 2003^13^ RCT | COPD, Other | BPAP NOS | NR | IPAP, EPAP | NR | -IPAP: 11.8 ± 0.6 cm H2O; -EPAP: 4.5 ± 0.4 cm H2O
Windisch, 2006^69^ Observational | HMV (pressure controlled ventilation) | PV401(Breas Medical AB; Moelnlycke, Sweden) | inspiratory pressure, PEEP, inspiratory time, rate | NR | -IPAP: 23.2 ± 2.8 mbar; -Rate: 20.5 ± 1.9 breaths/minute; -Inspiratory time 1.2 ± 0.1 seconds

Note: ± denotes standard deviation

cm: Centimeter, COPD: Chronic obstructive pulmonary diseases, EPAP: Expiratory positive airway pressure, FDA: Food and Drug Administration, H2O: Hydrogen dioxide, IPAP: Inspiratory Positive Airway Pressure, ml: milliliter, kg: kilogram, NMD: Neuromuscular Disease, NR: Not reported, OHS: Obesity hypoventilation syndrome, PEEP: positive end expiratory pressure, TRD: Thoracic Restrictive Disease

## KQ4 What respiratory services, other than the technical support of the use of the prescribed equipment, are being provided to the patients in the home?

Table F.24 COPD – Respiratory services

Author, Year, Study Design | Device/Mode | Respiratory Services delivered in the home (including by whom and how frequently)
Murphy, 2017^46^ RCT | BPAP ST | -Smoking cessation NOS; -COPD education NOS
Oscroft, 2014^50^ RCT | BPAP iVAPS versus BPAP ST | -24 hour hotline NOS
Bhatt, 2013^4^ RCT | BPAP NOS | -Daily phone call by respiratory therapist during first week; -One home visit by respiratory therapist during first week
Duiverman, 2011^22,^ ^23^ RCT | BPAP ST | -Supervision by specialized nurse NOS
Oscroft, 2010^48^ Observational | BPAP ST started after AECOPD versus BPAP ST started in stable patient without exacerbation | -24 hour hotline NOS
Crespo, 2009^18^ Observational | HMV (pressure or volume NOS) | -Emergency phone number
Cheung, 2010^12^ RCT | BPAP ST versus CPAP | -Nurse hotline NOS
McEvoy, 2009^43^ RCT | BPAP S | -Telephone calls answered by nurses as needed
Casanova, 2000^10^ RCT | BPAP S | -“Close contact was maintained” for first 3 weeks
Garrod, 2000 ^30^ RCT | BPAP S | -Phone call every 2 weeks to encourage use
Clini, 1996^14^ Observational | BPAP ST | -Home care program (initial evaluation of physical, occupational, and dietary needs; monthly physician visits; monthly education about treatments and correct medication use and coping strategies; periodic phone calls).
Köhnlein, 2014^37^ RCT | BPAP ST | -24 hour hotline staffed by health-care providers and specialized nurses
Gay, 1996^28^ RCT | BPAP ST | -Regular phone calls to ensure compliance.
Durao, 2018^25^ RCT | HMV/BPAP mix | -Smoking cessation NOS
Tsolaki, 2011^66^, Observational | BPAP ST | -Full technical support when required by “technically skilled personnel”

Medical services not reported: oxygen use, disease optimization [such as inhalers, vaccination, etc.], scheduled rehospitalizations, regular office visits with physician, pulmonary rehabilitation

AECOPD: acute exacerbation of chronic obstructive pulmonary disorder, BPAP: Bilevel Positive Airway Pressure, COPD; chronic obstructive pulmonary disease, CPAP: Continuous Positive Airway Pressure, HMV: Home Mechanical Ventilation, IVAPS: intelligent volume assured pressure support, NOS: Not otherwise Specified, PSV: pressure support ventilation, RCT: randomized controlled trail, S: spontaneous mode, ST: spontaneous/timed breath mode, VPAP: variable positive airway pressure

Table F.25 Thoracic Restrictive Disorders – Respiratory services

Author, Year, Study Design | Device/Mode | Respiratory Services delivered in the home (including by whom and how frequently)
Doménech-Clar, 2003^20^ Observational | BPAP NOS | -Telephone helpline (24 hours)
Tsolaki, 2011^66^ Observational | BPAP ST | -Full technical support when required by “technically skilled personnel”

Medical services not reported: oxygen use, disease optimization [such as inhalers, vaccination, etc.], scheduled rehospitalizations, regular office visits with physician, pulmonary rehabilitation

BPAP: Bilevel Positive Airway Pressure, NOS: Not otherwise Specified

Table F.26 Neuromuscular Disease – Respiratory services

Author, Year, Study Design | Device/Mode | Respiratory Services delivered in the home (including by whom and how frequently) | Outcome
Sanjuan-López, 2014^60^ Observational | HMV (PSV or ST) | -Telephone calls NOS; -Home visit from the equipment supply company nurse; -Mechanical cough assistance (Cough Assist, insufflator-exsufflator, MI-E, Emerson) was provided and caregiver training was provided if expectoration problems with a cough peak flow lower < 270 l/minute despite assisted cough physiotherapy.
Pinto, 2010^54^ Observational | BPAP ST + weekly telemonitoring versus BPAP ST without weekly telemonitoring | -Telephone helpline | The BPAP ST + Weekly telemonitoring group had significantly lower number of office visits (IRR: 0.34, 95% CI: 0.29 to 0.38); ER visits (IRR: 0.19; 95% CI: 0.10 to 0.37); hospital admission (IRR: 0.17; 95% CI: 0.07 to 0.41). There was no significant difference on mortality (OR: 1.00; 95% CI: 0.24 to 4.18) or median survival time (from BPAP adoption to death) (865 days vs. 334 days, p=0.13).
Doménech-Clar, 2003^20^ Observational | BPAP NOS | -Telephone helpline (24 hours)
Nauffal, 2002^47^ Observational | BPAP NOS | -Telephone helpline (24 hours)
Gonzalez-Bermejo, 2013^32^ Observational | BPAP ST | -Instruction on assisted cough techniques including mechanical insufflation-exufflation by a respiratory physiotherapist
Sancho, 2014^58^ Observational | HMV (volume cycled) versus BPAP ST | -Guideline based multidisciplinary care, management of cough impairment when necessary, nutritional support, and medical treatment with riluzole.
Coco, 2006^17^ Observational | BPAP ST | -Suction devices for secretion clearance; -All patients were also taught assisted cough techniques by an experienced respiratory physiotherapist, including mechanical insufflators-exsufflators.
Bourke, 2006^7^ RCT | BPAP ST | -Multidisciplinary clinical team review, education about assisted cough techniques, posture, bed raisers, adjustable beds, palliative care, hospice as needed.
Sancho, 2017^59^ Observational | HMV (volume assist control ventilation) | -Guideline based multidisciplinary care, management of cough impairment when necessary, nutritional support, and medical treatment with riluzole.
Farrero, 2005^26^ RCT | HMV/BPAP mix | -Salviary aspirator if ineffective cough; -Training of caregivers using assisted cough maneuvers and hyperinflation with a compressible ventilator bag or volume ventilator
Tsolaki, 2011^66^ Observational | BPAP ST | -Full technical support when required by “technically skilled personnel”

Medical services not reported: oxygen use, disease optimization [such as inhalers, vaccination, etc.], scheduled rehospitalizations, regular office visits with physician, pulmonary rehabilitation

BPAP: Bilevel Positive Airway Pressure, CI: confidence interval, ER: emergency room, HMV: Home Mechanical Ventilation, IRR: incidence rate ratio, NOS: Not otherwise Specified, OR: odds ratio, PSV: pressure support ventilation, RCT: randomized controlled trail, S: spontaneous mode, ST: spontaneous/timed breath mode, VPAP: variable positive airway pressure

Table F.27 Obesity Hypoventilation Syndrome – Respiratory services

Author, Year, Study Design | Device/Mode | Respiratory Services delivered in the home (including by whom and how frequently)
Masa, 2015^40^ ^41^ RCT | Mixed: HMV and BPAP mix (all with bilevel pressure with assured volume) | Lifestyle counseling: 1,000-calorie diet, correct sleep hygiene and habits (avoiding the supine decubitus position; maintaining regular sleep habits and exercise, not consuming sedatives, stimulants, or alcohol; not smoking tobacco; and avoiding heavy meals within 4 hours before bedtime).
Borel, 2011^6^ RCT | BPAP ST | Lifestyle counseling: 1 hour education session, patients were informed about the general health risks associated with obstructive sleep apnea and obesity (i.e., information about harmful lifestyle factors, such as smoking, reduced physical activity, and alcohol drinking). A specialized nurse provided dietary and lifestyle counseling, with the emphasis placed on diet, exercise, and modification of lifestyle in general, specifically focusing on eating behavior. The patients were advised to reduce fat by increasing their intake of fruits and vegetables and by limiting fatty meat, sweets, pastries, and desserts. The subjects were recommended to increase their overall level of daily physical activity.
Tsolaki, 2011^66^ Observational | BPAP ST | -Full technical support when required by “technically skilled personnel”

Medical services not reported: oxygen use, disease optimization [such as inhalers, vaccination, etc.], scheduled rehospitalizations, regular office visits with physician, pulmonary rehabilitation

BPAP: Bilevel Positive Airway Pressure, HMV: Home Mechanical Ventilation, OHS: obesity hypoventilation syndrome, RCT: randomized controlled trail, ST: spontaneous/timed breath mode

Table F.28 Mixed Diseases – Respiratory services

Author, Year, Study Design | Diseases | Device/Mode | Respiratory Services delivered in the home (including by whom and how frequently)
Munoz, 2005^44^ Observational | NMD/TRD | HMV volume assist/control mode versus HMV volume control mode | -Telephone helpline
Chiang, 2003^13^ RCT | COPD, other | BPAP NOS | -Telephone interviews by respiratory therapist every 2 weeks to assess compliance and ventilator usage.

Medical services not reported: oxygen use, disease optimization [such as inhalers, vaccination, etc.], scheduled rehospitalizations, regular office visits with physician, pulmonary rehabilitation

BPAP: Bilevel Positive Airway Pressure, COPD; chronic obstructive pulmonary disease HMV: Home Mechanical Ventilation, NMD: neuromuscular disease, NOS: not otherwise specified, RCT: randomized controlled trail, ST: spontaneous/timed breath mode, TRD: Thoracic Restrictive Disorder