# Appendix E Risk of Bias

Table E.1 Risk of bias for RCTs (Cochrane ROB tool) for included studies

Author, Year | Sequence Generation | Allocation Concealment | Blinding of Participants, Personnel | Blinding of Outcome Assessors | Incomplete Outcome Data | Selective Outcome Reporting | Other Sources of Bias | Overall RoB
Bertella, 2017^3^ | Low ROB | Low ROB | High ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB
Bhatt, 2013^4^ | Low ROB | Low ROB | High ROB | Unclear | Low ROB | Low ROB | High ROB | High ROB
Borel, 2011^6^ | Low ROB | Low ROB | High ROB | Low ROB | Low ROB | Unclear | High ROB | High ROB
Bourke, 2006^7^ | Low ROB | Unclear | High ROB | High ROB | Low ROB | Unclear | Low ROB | High ROB
Casanova, 2000^10^ | Low ROB | Unclear | High ROB | Low ROB | Unclear | Unclear | Unclear | High ROB
Cheung, 2010^12^ | Low ROB | Low ROB | High ROB | Unclear | High ROB | Low ROB | Low ROB | High ROB
Chiang, 2003^13^ | Low ROB | Unclear | High ROB | Unclear | Low ROB | Unclear | Low ROB | Moderate ROB
Clini, 2002^16^ | Unclear | Low ROB | High ROB | Low ROB | High ROB | Low ROB | High ROB | High ROB
De Backer, 2011^19^ | Unclear | Unclear | Unclear | Unclear | Low ROB | Unclear | Low ROB | Moderate ROB
Dreher, 2010^21^ | Unclear | Unclear | High ROB | High ROB | Low ROB | Unclear | High ROB | High ROB
Duiverman, 2008, 2011^22,^ ^23^ | Low ROB | Unclear | High ROB | Unclear | Low ROB | Low ROB | Low ROB | Moderate ROB
Duiverman, 2017^24^ | Unclear | Unclear | High ROB | High ROB | High ROB | Low ROB | High ROB | High ROB
Funk, 2010^27^ | Low ROB | Unclear | High ROB | High ROB | Low ROB | Low ROB | Low ROB | Moderate ROB
Garrod, 2000^30^ | Unclear | Low ROB | High ROB | Unclear | Low ROB | Unclear | Unclear | High ROB
Gay, 1996^31^ | Unclear | Unclear | High ROB | High ROB | Low ROB | Unclear | Unclear | High ROB
Hazenberg, 2014^33^ | Low ROB | Unclear | High ROB | High ROB | Low ROB | Low ROB | Low ROB | Moderate ROB
Howard, 2016^36^ | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB | High ROB | Moderate ROB
Köhnlein, 2014^37^ | Low ROB | Low ROB | High ROB | Low ROB | Low ROB | Low ROB | High ROB | High ROB
Marquez-Martin, 2014^38^ | Low ROB | Unclear | High ROB | Unclear | Low ROB | Unclear | Low ROB | Moderate ROB
Masa, 2015^40,^ ^41^ | Low ROB | Unclear | High ROB | Unclear | Low ROB | Unclear | Low ROB | Moderate ROB
Masa, 2016^42^ | Unclear | Unclear | High ROB | Unclear | Low ROB | High ROB | Low ROB | High ROB
McEvoy, 2009^43^ | Low ROB | Low ROB | High ROB | Unclear | Low ROB | Low ROB | Low ROB | Moderate ROB
Murphy, 2012^45^ | Unclear | Low ROB | High ROB | Unclear | Low ROB | Low ROB | Low ROB | Moderate ROB
Murphy, 2017^46^ | Low ROB | Low ROB | High ROB | Low ROB | Low ROB | Low ROB | High ROB | High ROB
Oscroft, 2010^49^ | Low ROB | Unclear | High ROB | Unclear | Low ROB | Low ROB | Low ROB | Moderate ROB
Oscroft, 2014^50^ | Low ROB | Low ROB | High ROB | High ROB | Low ROB | Unclear | High ROB | High ROB
Piper, 2008^55^ | Low ROB | Low ROB | Unclear | Unclear | Low ROB | Low ROB | Low ROB | Low ROB
Sin, 2007^62^ | Low ROB | Unclear | Low ROB | Low ROB | Unclear | Unclear | Unclear | Moderate ROB
Struik, 2014^64^ | Low ROB | Unclear | High ROB | Unclear | Low ROB | Low ROB | High ROB | Moderate ROB
Zhou, 2017^70^ | Low ROB | Low ROB | High ROB | Low ROB | Low ROB | Unclear | High ROB | High ROB

ROB: Risk of Bias

Table E.2 Risk of bias for observational studies (Newcastle-Ottawa Quality Assessment Scale) for included studies

Author, Year | Representativeness of the Study Population | Ascertainment of Exposure | Assessment of Outcome | Adequate of Followup | Conflict of Interest | Overall RoB
Aboussouan, 1997^1^ | Low ROB | Low ROB | Unclear | Low ROB | Unclear | Moderate ROB
Benhamou, 1997^2^ | High ROB | Low ROB | Low ROB | Low ROB | Unclear | High ROB
Blankenburg, 2017^5^ | Low ROB | Low ROB | Low ROB | High ROB | Low ROB | Moderate ROB
Budweiser, 2007^8^ | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB
Buyse, 2003^9^ | Low ROB | Low ROB | Low ROB | Low ROB | Unclear | Moderate ROB
Castillejo, 2014^11^ | High ROB | Low ROB | Low ROB | Low ROB | Unclear | High ROB
Clini, 1996^14^ | High ROB | Low ROB | Low ROB | Low ROB | Unclear | High ROB
Clini, 1998^15^ | High ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB
Coco, 2006^17^ | Low ROB | Low ROB | Low ROB | Low ROB | Unclear | Low ROB
Crespo, 2009^18^ | High ROB | High ROB | High ROB | Low ROB | Unclear | High ROB
Doménech-Clar, 2003^20^ | Low ROB | Low ROB | Low ROB | High ROB | Unclear | High ROB
Durao, 2018^25^ | Low ROB | Low ROB | Low ROB | Unclear | Low ROB | Low ROB
Farrero, 2005^26^ | Low ROB | Low ROB | Unclear | Low ROB | Unclear | Moderate ROB
Gad, 2014^28^ | Low ROB | Low ROB | High ROB | Low ROB | Low ROB | Moderate ROB
Galli, 2014^29^ | Low ROB | Low ROB | Low ROB | Low ROB | High ROB | Low ROB
Gonzalez-Bermejo, 2013^32^ | High ROB | High ROB | High ROB | Low ROB | Unclear | High ROB
Heinemann, 2011^34^ | Low ROB | Low ROB | High ROB | Low ROB | Unclear | High ROB
Hitzl, 2009^35^ | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB
Masa, 2000 ^39^ | High ROB | Low ROB | Low ROB | Low ROB | Low ROB | Moderate ROB
Munoz, 2005^44^ | Low ROB | Low ROB | Low ROB | Low ROB | Unclear | Moderate ROB
Nauffal, 2002^47^ | Low ROB | Low ROB | Low ROB | Low ROB | Unclear | Moderate ROB
Oscroft, 2010^48^ | High ROB | Low ROB | Low ROB | Low ROB | Unclear | Moderate ROB
Paone, 2014^51^ | Low ROB | Low ROB | Low ROB | High ROB | Low ROB | Low ROB
Perez de Llano, 2005^52^ | Low ROB | Low ROB | Low ROB | Low ROB | Unclear | Low ROB
Pinto, 1995^53^ | High ROB | Low ROB | Low ROB | Low ROB | Unclear | High ROB
Pinto, 2010^54^ | Low ROB | Low ROB | Low ROB | Low ROB | High ROB | High ROB
Priou, 2010^56^ | Low ROB | Low ROB | Unclear | Low ROB | Low ROB | Moderate ROB
Salturk, 2015^57^ | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB
Sancho, 2014^58^ | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB | Low ROB
Sancho, 2017^59^ | High ROB | Low ROB | Unclear | Unclear | Low ROB | High ROB
Sanjuan-López, 2014^60^ | Low ROB | High ROB | Low ROB | Low ROB | Low ROB | High ROB
Schonhofer, 2001^61^ | High ROB | Low ROB | Unclear | Unclear | Unclear | High ROB
Sivori, 2007^63^ | Low ROB | Low ROB | High ROB | Unclear | Low ROB | Moderate ROB
Tsolaki, 2008^65^ | High ROB | Low ROB | High ROB | Low ROB | Unclear | High ROB
Tsolaki, 2011^66^ | Low ROB | Low ROB | Low ROB | Low ROB | Unclear | Low ROB
Vasquez, 2017^67^ | Low ROB | Low ROB | Unclear | Unclear | Unclear | Moderate ROB
Vitacca, 2017^68^ | Low ROB | Unclear | Unclear | Low ROB | Low ROB | Moderate ROB
Windisch,2006^69^ | Low ROB | Low ROB | Low ROB | Unclear | Unclear | Moderate ROB

ROB: Risk of Bias