# Appendix D Characteristics of Included Studies

Table D.1 Characteristics of included studies

Author, Year | Study Country, Study Design, Study Period | Risk of Bias | Inclusion / Exclusion Criteria | Intervention and comparisons (Groups) | Device used (HMV, CPAP, BPAP) manufacturer, brand name, model no. | Patient Characteristics | Disease
Aboussouan, 1997^1^ | Observational in United States, 03/1993 to 02/1996 | Moderate ROB | Inclusion: ALS via el Escorial criteria; dyspnea on exertion or PaCO2 ≥ 45 mmHg or orthopnea or FVC < 60% predicted. | HMV/BPAP mix (tolerant) | [underlined: HMV]; PLV-100; Life Care Products (Lafayette, Colorado, USA); (FDA approved 510(k) clearance); [underlined: BPAP]; BiPAP; Respironics Inc. (Murrysville, Pennsylvania, USA); (FDA approved 510(k) clearance) | 18 Patients aged 61.5 ± 11.9, 22.2% female | NMD
Aboussouan, 1997^1^ | Observational in United States, 03/1993 to 02/1996 | Moderate ROB | Inclusion: ALS via el Escorial criteria; dyspnea on exertion or PaCO2 ≥ 45 mmHg or orthopnea or FVC < 60% predicted. | HMV/BPAP mix (intolerant) | | 21 Patients aged 61.8 ± 15.2, 33.3% female | NMD
Benhamou, 1997^2^ | Observational comparative case-control study in France | High ROB | Inclusion: Treated by home non-invasive mechanical ventilation & LTOT for severe chronic respiratory failure from diffuse bronchiectasis. | HMV (volume assist control ventilation) | [underlined: HMV]; Monnal D; Taema (Antony, France); (Not FDA approved) | 14 Patients aged 64±10 | Other
Benhamou, 1997^2^ | Observational comparative case-control study in France | High ROB | Inclusion: Treated by home non-invasive mechanical ventilation & LTOT for severe chronic respiratory failure from diffuse bronchiectasis. | Oxygen alone | No PAP | 14 Patients aged 66±9 | Other
Bertella, 2017^3^ | RCT in Italy, 03/2011-03/2014 | Low ROB | Inclusion: ALS (definite via El Esocrial Criteria), stable disease (no respiratory infection in prior 3 months); Exclusion: cognitive impairment, severe comorbidity, contraindications to NIV, distance from hospital >40 km. | BPAP volume assured pressure support ventilation inpatient initiation | [underlined: BPAP]; Trend II ST 30; Hoffrichter (Schwerin, Germany); (Not FDA approved); BiPAP Synchrony II; Philips Respironics (Murrysville, PA, USA); (FDA approved 510(k) clearance) | 25 patients aged 65.92±10.18, 32% female | NMD
Bertella, 2017^3^ | RCT in Italy, 03/2011-03/2014 | Low ROB | | BPAP volume assured pressure support ventilation outpatient initiation | [underlined: BPAP]; Trend II ST 30; Hoffrichter (Schwerin, Germany); (Not FDA approved); BiPAP Synchrony II; Philips Respironics (Murrysville, PA, USA); (FDA approved 510(k) clearance) | 25 patients aged 61.26±8.64, 44% female | NMD
Bhatt, 2013^4^ | RCT in USA | High ROB | Inclusion: Stable COPD with 10 pack year smoking history, low clinical probability of OSA; Exclusion: Congestive heart failure, OSA, chronic respiratory conditions other than COPD, age<35 years, diseases limiting life expectancy <2 years, active malignancies in previous 2 years, process precluding a nasal mask. | BPAP NOS | [underlined: BPAP]; BiPAP Synchrony; Respironics Inc.; (FDA approved 510(k) clearance) | 15 Patients, 47% female | COPD
Bhatt, 2013^4^ | RCT in USA | High ROB | | No BPAP | No PAP | 12 Patients aged 68 (IQR 65-78), 0% female | COPD
Blankenburg, 2017^5^ | Observational, Prospective in Germany, 01/01/2011 to 12/31/2011 | Moderate ROB | Inclusion: COPD (GOLD criteria NOS), PaCO2>7.0kPa, pH>7.35, stable disease (no exacerbation in 2 weeks prior); Exclusion: decompensated heart failure or “other conditions” that cause chronic respiratory failure, systemic corticosteroids | HMV (pressure controlled ventilation or pressure support ventilation) | [underlined: HMV]; VS III; ResMed (Saime SA, France); (FDA approved 510(k) clearance) | 51 patients aged 66.9 (SE 1.3), 37% female | COPD
Blankenburg, 2017^5^ | Observational, Prospective in Germany, 01/01/2011 to 12/31/2011 | Moderate ROB | Inclusion: OHS (BMI >30kg/m2, chronic daytime hypercapnia PaCO2>6.7kPa, pH>7.35), symptoms of hypercapnia NOS); Exclusion: decompensated heart failure or “other conditions” that cause chronic respiratory failure | HMV (pressure controlled ventilation or pressure support ventilation) | [underlined: HMV]; VS III; ResMed (Saime SA, France); (FDA approved 510(k) clearance) | 34 patients aged 65.4 (SE 1.8), 50% female | OHS
Borel, 2011^6^ | RCT in Switzerland | High ROB | Inclusion: Age 20-75 years, BMI >30; Exclusion: Declined or presented any significant airway obstruction, scoliosis, cardiac failure, progressive NMD. | BPAP ST | [underlined: BPAP]; GoodKnight-425ST; Covidien; (FDA approved 510(k) clearance) | 19 Patients aged 58±11, 56% female | OHS
Borel, 2011^6^ | RCT in Switzerland | High ROB | Inclusion: Age 20-75 years, BMI >30; Exclusion: Declined or presented any significant airway obstruction, scoliosis, cardiac failure, progressive NMD. | Lifestyle counseling | No PAP | 18 Patients aged 54±6, 59% female | OHS
Bourke, 2006^7^ | RCT in United Kingdom, 03/2000 to 12/2003 | High ROB | Inclusion:; Exclusion: Current or previous NIPPV use, significant comorbidities, age>75 years, inability to complete quality of life assessment. | BPAP ST (full cohort) | [underlined: BPAP]; VPAP STII; ResMed United Kingdom Ltd (Abingdon, United Kingdom); (FDA approved 510(k) clearance) | 22 Patients aged 63.7±10.3, 36% female | NMD
Bourke, 2006^7^ | RCT in United Kingdom, 03/2000 to 12/2003 | High ROB | Inclusion:; Exclusion: Current or previous NIPPV use, significant comorbidities, age>75 years, inability to complete quality of life assessment. | No BPAP ST (full cohort) | No PAP | 19 Patients aged 63±8.1, 47% female | NMD
Bourke, 2006^7^ | RCT in United Kingdom, 03/2000 to 12/2003 | High ROB | Inclusion:; Exclusion: Current or previous NIPPV use, significant comorbidities, age>75 years, inability to complete quality of life assessment. | BPAP ST (good bulbar patients) | BPAP good bulbar | 11 Patients | NMD
Bourke, 2006^7^ | RCT in United Kingdom, 03/2000 to 12/2003 | High ROB | Inclusion:; Exclusion: Current or previous NIPPV use, significant comorbidities, age>75 years, inability to complete quality of life assessment. | No BPAP ST (good bulbar patients) | No PAP good bulbar | 9 Patients | NMD
Bourke, 2006^7^ | RCT in United Kingdom, 03/2000 to 12/2003 | High ROB | Inclusion:; Exclusion: Current or previous NIPPV use, significant comorbidities, age>75 years, inability to complete quality of life assessment. | BPAP ST (poor bulbar patients) | BPAP poor bulbar | 11 Patients | NMD
Bourke, 2006^7^ | RCT in United Kingdom, 03/2000 to 12/2003 | High ROB | Inclusion:; Exclusion: Current or previous NIPPV use, significant comorbidities, age>75 years, inability to complete quality of life assessment. | No BPAP ST (poor bulbar patients) | No PAP poor bulbar | 10 Patients | NMD
Budweiser, 2007^8^ | Observational Prospective in Germany, 01/2002 to 12/2005 | Low ROB | Inclusion: Less than 80 years old, severe COPD (GOLD IV), FEV1/FVC <70%, FEV1 <50% predicted, PaCO2 > 50mmHg after therapy/treatment for exacerbation; Exclusion: Malignancy diagnosis within prior 5 years, intubation or tracheostomy prior to NIPPV | BPAP (pressure controlled ventilation) | [underlined: BPAP]; Twin Air; Airox Inc. (Pau, France); (Not FDA approved); Smart Air; Airox Inc. (Pau, France); (Not FDA approved); BiPAP Synchrony; Respironics Inc. (Murrysville, USA); (FDA approved 510(k) clearance) | 99 Patients aged 34.2±8.4, 36.4% female | COPD
Budweiser, 2007^8^ | Observational Prospective in Germany, 01/2002 to 12/2005 | Low ROB | | No BPAP | No PAP | 41 Patients aged 66.6±8.6, 31.7% female | COPD
Buyse, 2003^9^ | Observational Retrospective in Belgium, 09/1990 to 03/2001 | Moderate ROB | Inclusion: Consecutive kyphoscoliosis & respiratory insufficiency patients started on LTOT and/or NIPPV at center. | HMV (volume or pressure cycled ventilator NOS) + oxygen | [underlined: HMV]; Eole 3; Saime (Savigny-Le-Temple, France); (Not FDA approved); O’nyx; Nellcor Puritan Bennet (Villers-les-Nancy, France); (FDA approved 510(k) clearance) | 18 Patients aged 61±7, 77.8% female | TRD
Buyse, 2003^9^ | Observational Retrospective in Belgium, 09/1990 to 03/2001 | Moderate ROB | Inclusion: Consecutive kyphoscoliosis & respiratory insufficiency patients started on LTOT and/or NIPPV at center. | Oxygen alone | No PAP | 15 Patients aged 62±7, 66.66% female | TRD
Casanova, 2000^10^ | RCT in Spain, 1995 to 1997 | High ROB | Inclusion: Age 45-75 years, smoking history 20 pack years, clinically stable; Exclusion: Refusal to stop smoking, OSA, >10 apnea-hypopnea episodes per hour, other etiologies of chronic airway obstruction, significant comorbidities. | BPAP S + standard care | [underlined: BPAP]; DP-90; Taema (Paris, France); (Not FDA approved) | 20 Patients aged 64±5, 0% female | COPD
Casanova, 2000^10^ | RCT in Spain, 1995 to 1997 | High ROB | | Standard care | No PAP | 24 Patients aged 68±4, 4% female | COPD
Castillejo, 2014^11^ | Observational Prospective in Spain, 1998 to 2010 | High ROB | Inclusion: OHS & BMI >30; Exclusion: Obstructive disease with FEV1/FVC ratio <70%, NMD with respiratory involvement, respiratory disease other than OHS. | BPAP ST in OHS without OSA | [underlined: BPAP]; Harmony BiPAP; Respironics (Louisville, USA); (FDA approved 510(k) clearance) | 50 Patients aged 64.62±9.8, 82% female | OHS
Castillejo, 2014^11^ | Observational Prospective in Spain, 1998 to 2010 | High ROB | Inclusion: OHS & BMI >30; Exclusion: Obstructive disease with FEV1/FVC ratio <70%, NMD with respiratory involvement, respiratory disease other than OHS. | BPAP ST in OHS with OSA | [underlined: BPAP]; Harmony BiPAP; Respironics (Louisville, USA); (FDA approved 510(k) clearance) | 33 Patients aged 64.47±8.2, 57.6% female | OHS
Cheung, 2010^12^ | RCT in China, 01/2007 to 03/2009 | High ROB | Inclusion: Severe exacerbation with persistent respiratory acidosis (despite treatment with bronchodilators, corticosteroids, antibiotics), required NIPPV treatment; Exclusion: Active smokers, RF from non-COPD cause, evidence of pneumonia, transmissible infections, requiring long-term systemic steroids, comorbidity giving life expectancy <1 year, significant OSA, already on home NIPPV, inability to comply with study protocol. | CPAP | [underlined: CPAP]; BiPAP Synchrony; Respironics Inc. (Murrysville, USA); (FDA approved 510(k) clearance) | 24 Patients aged 71±7.7, 8.3% female | COPD
Cheung, 2010^12^ | RCT in China, 01/2007 to 03/2009 | High ROB | | BPAP ST | [underlined: BPAP]; BiPAP Synchrony; Respironics Inc. (Murrysville, USA); (FDA approved 510(k) clearance) | 23 Patients aged 69.5±7.8, 8.7% female | COPD
Chiang, 2003^13^ | RCT in Taiwan, 06/2001 to 11/2002 | Moderate ROB | Inclusion: Diagnosed with COPD and asthma and bronchiectasis, repeat admission due to lung deterioration despite treatment, well-motivated, sleepy during day or headache upon waking in morning; Exclusion: Uncooperative, poor motivation, unable to tolerate nocturnal nasal positive pressure ventilation, OSA, unable to perform 6-minute walk distance test due to other disease. | BPAP NOS | [underlined: BPAP]; BiPAP; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 13 Patients aged 62.5±11.5, 23.1% female | Mixed(COPD, Other)
Chiang, 2003^13^ | RCT in Taiwan, 06/2001 to 11/2002 | Moderate ROB | | no BPAP NOS | No PAP | 14 Patients aged 65.5±10, 35.7% female | Mixed(COPD, Other)
Clini, 1996^14^ | Observational Prospective in Italy, 12/1991 to 09/1992 | High ROB | Inclusion: Severe COPD, ≥1 admission due to severe exacerbation in prior 18 months; Exclusion: Suspicion of sleep apnea, comorbidities making patients unsuitable for long-term trials | BPAP ST + home care + oxygen | [underlined: BPAP]; BiPAP; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 17 Patients aged 62±5, 29.4% female | COPD
Clini, 1996^14^ | Observational Prospective in Italy, 12/1991 to 09/1992 | High ROB | Inclusion: Severe COPD, ≥1 admission due to severe exacerbation in prior 18 months; Exclusion: Suspicion of sleep apnea, comorbidities making patients unsuitable for long-term trials | Home care + oxygen | No PAP | 17 Patients aged 67±7, 47% female | COPD
Clini, 1996^14^ | Observational Prospective in Italy, 12/1991 to 09/1992 | High ROB | Inclusion: Severe COPD, ≥1 admission due to severe exacerbation in prior 18 months; Exclusion: Suspicion of sleep apnea, comorbidities making patients unsuitable for long-term trials | Oxygen | No PAP | 29 Patients aged 62±8, 34.5% female | COPD
Clini, 1998^15^ | Observational Prospective in Italy, 12/1991 to 12/1994 | Low ROB | Inclusion: Clinically stable, ≥1 ICU admission due to severe exacerbation within 2 years prior, care-giver at home, geographical allocation allowing access to the hospital; Exclusion: other organ failure, cancer, inability to cooperate to long-term trials, suspicion of sleep apnea. | BPAP ST + oxygen | [underlined: BPAP]; BiPAP; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 28 Patients aged 66±6, 21.4% female | COPD
Clini, 1998^15^ | Observational Prospective in Italy, 12/1991 to 12/1994 | Low ROB | | Oxygen | No PAP | 21 Patients aged 66±8, 33% female | COPD
Clini, 2002^16^ | RCT in Italy/France, 06/1996 to 01/2000 | High ROB | Inclusion: Age ≤75 years, LTOT ≥ 6 months, dyspnea score (assessed by Medical Research Council) ≥2, FEV1 <1.5 liters, FEV1/FVC <60%, TLC ≥90% predicted, PaCO2 >6.6 kPa, PaO2 <7.8 kPa breathing room at rest; Exclusion: 15% increase FEV1 after salbutamol, pH ≤7.34, active smokers, history of OSA (defined by apnea-hypopnea index >10 episodes per hour), therapy with systemic steroids, concomitant chronic systemic diseases (HF, diabetes, infections, neoplasm, etc.), other chronic respiratory diseases (fibrothorax, bronchiectasis, cystic fibrosis), home care program other than LTOT | BPAP ST + LTOT | [underlined: BPAP]; BiPAP ST 30; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 39 Patients aged 64±7, 18% female | COPD
Clini, 2002^16^ | RCT in Italy/France, 06/1996 to 01/2000 | High ROB | | LTOT | No PAP | 47 Patients aged 66±14, 21.3% female | COPD
Coco, 2006^17^ | Observational Prospective in Italy, 10/1999 to 07/2003 | Low ROB | Inclusion: Definite/probable ALS; Exclusion: Primary lateral sclerosis, diagnosis other than ALS during followup. | BPAP ST (use ≥ 4 hours/day) | [underlined: BPAP]; BiPAP; Respironics (Vitalaire, Italy); (FDA approved 510(k) clearance) | 44 Patients aged 62.3±11.4, 31.8% female | NMD
Coco, 2006^17^ | Observational Prospective in Italy, 10/1999 to 07/2003 | Low ROB | Inclusion: Definite/probable ALS; Exclusion: Primary lateral sclerosis, diagnosis other than ALS during followup. | BPAP ST < 4 hours/day) | [underlined: BPAP]; BiPAP; Respironics (Vitalaire, Italy); (FDA approved 510(k) clearance) | 27 Patients aged 61.1±9.9, 40.7% female | NMD
Crespo, 2009^18^ | Observational Retrospective in Spain, 1998 to 2001 | High ROB | Inclusion: Stable disease initiating scheduled HMV with nasal mask; Exclusion: Invasive ventilation by tracheostomy, NIPPV with face mask/mouthpiece, HMV with nasal mask started during acute phase of disease. | HMV (pressure or volume NOS) in age ≥ 75 years old | [underlined: HMV] NOS | 10 Patients aged 76.9±2.1, 30% female | Mixed (COPD, TRD, NMD, OHS, Other)
Crespo, 2009^18^ | Observational Retrospective in Spain, 1998 to 2001 | High ROB | | HMV (pressure or volume NOS) in 65-74 years old | [underlined: HMV] NOS | 40 Patients aged 69.5±3.2, 45% female | Mixed (COPD, TRD, NMD, OHS, Other)
Crespo, 2009^18^ | Observational Retrospective in Spain, 1998 to 2001 | High ROB | | HMV (pressure or volume NOS) in <65 years old | [underlined: HMV] NOS | 41 Patients aged 52.7±12.0, 54% female | Mixed (COPD, TRD, NMD, OHS, Other)
De Backer, 2011^19^ | RCT in Belgium | Moderate ROB | Inclusion: Age 18-80 years, COPD stage III/IV, exacerbation hospitalization, persisting hypercapnia, stopped smoking, no home NIPPV before admission; Exclusion: Invasive ventilation, asthmatic, restrictive lung disease, malignancy, heart failure, OSA. | BPAP NOS | [underlined: BPAP]; BiPAP synchrony; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 10 Patients aged 65±7 | COPD
De Backer, 2011^19^ | RCT in Belgium | Moderate ROB | | Standard care | No PAP | 5 Patients aged 66±6 | COPD
Domenéch-Clar, 2003^20^ | Observational Prospective in Spain, 01/1997 to 11/2001 | High ROB | Inclusion: Hospitalized 48-72 hours, moderate to severe restrictive respiratory disorder from TWD or NMD, clinically stable. | BPAP NOS in thoracic wall diseases | [underlined: BPAP]; DP-90; Taema (Paris, France); (FDA approved 510(k) clearance) | 27 Patients aged 55.6, 40.7% female | TRD
Domenéch-Clar, 2003^20^ | Observational Prospective in Spain, 01/1997 to 11/2001 | High ROB | Inclusion: Hospitalized 48-72 hours, moderate to severe restrictive respiratory disorder from TWD or NMD, clinically stable. | BPAP NOS in neuromuscular diseases | [underlined: BPAP]; DP-90; Taema (Paris, France); (FDA approved 510(k) clearance) | 18 Patients aged 42.5, 50% female | NMD
Dreher, 2010^21^ | RCT in Germany | High ROB | Inclusion: CHRF due to COPD stage IV; Exclusion: Acute RF, invasive ventilation via tracheostomy, weaned from invasive ventilation, intubated during prior 3 months, other ventilatory support prior to study. | HMV (pressure assist/control) (time period 1) | [underlined: HMV]; Breas Vivo 40; Breas Medical AB (Molnlycke, Sweden); (FDA approved 510(k) clearance); Smart Air; Airox (Pau Cedex, France); (Not FDA approved) | 9 Patients | COPD
Dreher, 2010^21^ | RCT in Germany | High ROB | | HMV (PSV ST) (time period 1) | [underlined: HMV]; Breas Vivo 40; Breas Medical AB (Molnlycke, Sweden); (FDA approved 510(k) clearance); Smart Air; Airox (Pau Cedex, France); (Not FDA approved) | 8 Patients | COPD
Dreher, 2010^21^ | RCT in Germany | High ROB | | HMV (PSV ST) (time period 2) | [underlined: HMV]; Breas Vivo 40; Breas Medical AB (Molnlycke, Sweden); (FDA approved 510(k) clearance); Smart Air; Airox (Pau Cedex, France); (Not FDA approved) | 8 Patients | COPD
Dreher, 2010^21^ | RCT in Germany | High ROB | | HMV (pressure assist/control) (time period 2) | [underlined: HMV]; Breas Vivo 40; Breas Medical AB (Molnlycke, Sweden); (FDA approved 510(k) clearance); Smart Air; Airox (Pau Cedex, France); (Not FDA approved) | | COPD
Duiverman, 2011^22^ ^23^ | RCT in Netherlands | Moderate ROB | Inclusion: COPD stage III/IV, age 40-76 years, clinically stable, chronic hypercapnic RF; Exclusion: cardiac/neuromuscular disease limiting exercise tolerance, exposure to pulmonary rehab program (previous 18 months), previous exposure to chronic NIPPV ever, apnea-hypopnea index ≥10h. | BPAP ST + pulmonary rehabilitation | [underlined: BPAP]; BiPAP Synchrony; Respironics Inc.; (FDA approved 510(k) clearance) | 24 Patients aged 63±10, 33.3% female | COPD
Duiverman, 2011^22^ ^23^ | RCT in Netherlands | Moderate ROB | | Pulmonary rehabilitation alone | No PAP | 32 Patients aged 61±8, 46.9% female | COPD
Duiverman, 2017^24^ | RCT in Netherlands | High ROB | Inclusion: COPD (GOLD III or IV), ≥ 2 AECOPD with acute hypercapnic respiratory failure (pH<7.35) per year, daytime Inclusion: PaCO2 ≥6.7 kPa (50 mmHg) or nocturnal PaCO2 ≥7.3 kPa (55 mmHg) or nighttime rise in PtCO2 ≥1.3 kPa (10 mmHg), stable (no AECOPD in prior 4 weeks, pH>7.35).; Exclusion: TRD, NMD | HMV/BPAP mix (pressure controlled ventilation) (high intensity) | [underlined: HMV]; Vivo 50; Breas Medical (Molndal, Sweden); (FDA approved 510(k) clearance); [underlined: BPAP]; Stellar 100; Resmed (Martinsried, Germany); (FDA approved 510(k) clearance) | Crossover – 11 patients aged 68.7±8.5, 54% female | COPD
Duiverman, 2017^24^ | RCT in Netherlands | High ROB | | HMV/BPAP mix (pressure support ventilation) (low intensity) | [underlined: HMV]; Vivo 50; Breas Medical (Molndal, Sweden); (FDA approved 510(k) clearance); [underlined: BPAP]; Stellar 100; Resmed (Martinsried, Germany); (FDA approved 510(k) clearance) | Crossover – 11 patients aged 68.7±8.5, 54% female | COPD
Durao, 2018^25^ | Observational Retrospective in Portugal, 08/1/2011 to 07/31/2014 | Low ROB | Inclusion: COPD NOS; Exclusion: No clinical assessment in prior 6 months, OSA with a history of noncompliance with CPAP | HMV/BPAP mix started in AECOPD | [underlined: BPAP]; VPAP ST S9; Resmed; (FDA approved 510(k) clearance); VPAP ST STA; Resmed; (FDA approved 510(k) clearance); BIPAP PR1; Philips Respironics; (FDA approved 510(k) clearance); BiPAP A30; Philips Respironics; (FDA approved 510(k) clearance); BiPAP A40; Philips Respironics; (FDA approved 510(k) clearance); [underlined: HMV]; Trilogy 100; Philips Respironics; (FDA approved 510(k) | 62 patients aged 64.6±10.4, 12.9% female | COPD
Durao, 2018^25^ | Observational Retrospective in Portugal, 08/1/2011 to 07/31/2014 | Low ROB | Inclusion: COPD NOS; Exclusion: No clinical assessment in prior 6 months, OSA with a history of noncompliance with CPAP | HMV/BPAP mix started in stable disease | | 47 patients aged 66.9±8.4, 17% female | COPD
Farrero, 2005^26^ | Observational in Spain, 1988 to 12/2002 | Moderate ROB | Inclusion: ALS NOS | HMV/BPAP mix in pre protocol group | [underlined: HMV]; PLV-100; Life Care Products; (FDA approved 510(k) clearance); PV 501; BREAS Medical (Gothenburg, Sweden); (FDA approved 510(k) clearance); [underlined: BPAP]; BiPAP; Respironics; (FDA approved 510(k) clearance); VPAP ST II; Sullivan; (FDA approved 510(k) clearance) | 11 Patients aged 53 ± 11 | NMD
Farrero, 2005^26^ | Observational in Spain, 1988 to 12/2002 | Moderate ROB | Inclusion: ALS NOS | HMV/BPAP mix in post protocol group | | 48 Patients aged 62 ± 10 | NMD
Funk, 2010^27^ | RCT in Austria, 04/01/2003 to 02/28/2007 | Moderate ROB | Inclusion: COPD requiring invasive/non-invasive mechanical ventilation due to acute RF, clinically stable, hypercapnic; Exclusion: Severe psychiatric disorder likely to impair NIPPV compliance, other severe pulmonary diseases not COPD, other severe non-pulmonary diseases limiting prognosis, noncompliance to NIPPV, women of childbearing age, evidence of sleep apnea. | BPAP NOS | BPAP - Not reported (“various types of patient-triggered bi-level positive pressure ventilators were used”) | 13 Patients aged 62±6, 46% female | COPD
Funk, 2010^27^ | RCT in Austria, 04/01/2003 to 02/28/2007 | Moderate ROB | | Standard care | No PAP | 13 Patients aged 65±6, 38% female | COPD
Gad, 2014^28^ | Observational Prospective in Egypt, 10/2012 to 04/2014 | Moderate ROB | Inclusion: Severe COPD stage III/IV, FEV1/FVC <70%, clinically stable; Exclusion: invasive mechanical ventilation, OSA, cardiac disease limiting exercise tolerance, NMDs, orthopedic impairment of shoulder girdle | BPAP ST + exercise program | BPAP | 15 Patients aged 65.70±10, 40% female | COPD
Gad, 2014^28^ | Observational Prospective in Egypt, 10/2012 to 04/2014 | Moderate ROB | | Exercise program | No PAP | 15 Patients aged 66.41±9, 26.7% female | COPD
Galli, 2014^29^ | Observational Retrospective in USA, 01/2011 to 12/2011 | High ROB | Inclusion: Primary/secondary discharge diagnosis of AECOPD, hypercapnic RF during hospitalization; Exclusion: discharged to hospice, no documented hypercapnia, not receiving NIPPV during hospitalization. | BPAP NOS post hospital admission | BPAP | 78 Patients aged 61.6±10.2, 57.7% female | COPD
Galli, 2014^29^ | Observational Retrospective in USA, 01/2011 to 12/2011 | High ROB | | No BPAP post hospital admission | No PAP | 88 Patients aged 64.9±10.8, 67% female | COPD
Garrod, 2000^30^ | RCT in England | High ROB | Inclusion: Severe COPD, all patients had limited exercise tolerance due to dyspnea and no previous exposure to NIPPV; Exclusion: unstable angina, intermittent claudication, and other mobility-limiting conditions. | BPAP S + pulmonary rehabilitation | [underlined: BPAP]; BiPAP ST 30; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 23 Patients aged 63 | COPD
Garrod, 2000^30^ | RCT in England | High ROB | | Pulmonary rehabilitation | No PAP | 22 Patients aged 67 | COPD
Gay, 1996^31^ | RCT in USA, 1989 to 1992 | High ROB | Inclusion: Age<80 years, BMI≤30, FEV1 <40%; Exclusion: activated for lung transplantation, active psychiatric disease that necessitated sedative or hypnotic meds, current use of nocturnal ventilation or continuous PAP, major illness likely to preclude completion of prolonged trial. | BPAP ST | [underlined: BPAP]; BiPAP; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 7 Patients aged 71.0±4.5, 28.6% female | COPD
Gay, 1996^31^ | RCT in USA, 1989 to 1992 | High ROB | | Sham BPAP ST (CPAP at lowest setting) | No Device | 6 Patients aged 66.5±9.1, 16.6% female | COPD
Gonzalez-Bermejo, 2013^32^ | Observational Retrospective in France, 01/01/2003 to 12/31/2007 | High ROB | Inclusion: 4h/night minimal adherence; Exclusion: Use of other ventilator types, without integrated SpO2 monitoring. | BPAP ST “correctly ventilated patients” | [underlined: BPAP]; VPAP-III or VPAP-IV Resmed (Sydney, Australia); (FDA approved 510(k) clearance) | 40 Patients aged 63±12, 32.5% female | NMD
Gonzalez-Bermejo, 2013^32^ | Observational Retrospective in France, 01/01/2003 to 12/31/2007 | High ROB | Inclusion: 4h/night minimal adherence; Exclusion: Use of other ventilator types, without integrated SpO2 monitoring. | BPAP ST “insufficiently ventilated patients” | [underlined: BPAP]; VPAP-III or VPAP-IV Resmed (Sydney, Australia); (FDA approved 510(k) clearance) | 42 Patients aged 64±10, 17% female | NMD
Hazenberg, 2014^33^ | RCT in Netherlands, 10/2008 to 10/2012 | Moderate ROB | Inclusion: Chronic RF from NMD or thoracic cage disorder, orthopnea from diaphragm paralysis & daytime normocapnia also included; Exclusion: Strictly COPD patients, not mask naive, acute RF, age < 18 years, invasive ventilation, nursing home residing.; (77 total patients in both groups, 3 patients on volume control, 74 patients on pressure control) | HMV started at home pressure controlled ventilation with change to volume assist control ventilation if not tolerated | [underlined: HMV]; Elisee 150; ResMed (Paris, France); (Not FDA approved) | 38 Patients aged 59.9±12.6, 47.4% female | Mixed (NMD, TRD)
Hazenberg, 2014^33^ | RCT in Netherlands, 10/2008 to 10/2012 | Moderate ROB | | HMV started in the hospital pressure controlled ventilation with change to volume assist control ventilation if not tolerated | [underlined: HMV]; Elisee 150; ResMed (Paris, France); (Not FDA approved) | 39 Patients aged 56.9±13.9, 35.9% female | Mixed (NMD, TRD)
Heinemann, 2011^34^ | Observational Retrospective in Germany, 01/2002 to 02/2008 | High ROB | Inclusion: COPD, prolonged weaning from invasive mechanical ventilation; Exclusion: Intubated from cardiogenic edema or cardiopulmonary resuscitation | BPAP (pressure controlled ventilation) | BPAP NOS | 39 Patients aged 64.6±10.8, 30.1% female | COPD
Heinemann, 2011^34^ | Observational Retrospective in Germany, 01/2002 to 02/2008 | High ROB | Inclusion: COPD, prolonged weaning from invasive mechanical ventilation; Exclusion: Intubated from cardiogenic edema or cardiopulmonary resuscitation | No BPAP | No PAP | 43 Patients aged 72.8±8.6, 25.6% female | COPD
Hitzl, 2009^35^ | Observational Prospective in Germany | Low ROB | Inclusion: HMV initiated ≥3 months prior to study, undergone bioelectrical impedance analysis measurement, regularly readmitted for routine followup, all had CHRF; Exclusion: OHS, progressive NMD, tracheostomy. | HMV (pressure controlled ventilation) in COPD | HMV NOS | 93 Patients aged 65.5±8, 30.1% female | COPD
Hitzl, 2009^35^ | Observational Prospective in Germany | Low ROB | | HMV (pressure controlled ventilation) in restrictive thoracic disease | HMV NOS | 38 Patients aged 64.9±11.3, 57.9% female | TRD
Howard, 2016^36^ | RCT in Australia, 11/01/2011 to 12/31/2013 | Moderate ROB | Inclusion: Primary OHS diagnosis; Exclusion: Other conditions contributing to hypoventilation. | BPAP ST | [underlined: BPAP]; Harmony; Philips Respironics (USA); (FDA approved 510(k) clearance); VPAP III STa; ResMed (Bella Vista, Australia); (FDA approved 510(k) clearance) | 29 Patients aged 53.2±10.7, 51.7% female | OHS
Howard, 2016^36^ | RCT in Australia, 11/01/2011 to 12/31/2013 | Moderate ROB | Inclusion: Primary OHS diagnosis; Exclusion: Other conditions contributing to hypoventilation. | CPAP | [underlined: CPAP]; Harmony; Philips Respironics (USA); (FDA approved 510(k) clearance); VPAP III STa; ResMed (Bella Vista, Australia); (FDA approved 510(k) clearance) | 31 Patients aged 52.9±10, 41.9% female | OHS
Köhnlein, 2014^37^ | RCT in Germany and Austria, 10/29/2004 to 07/31/2011 | High ROB | Inclusion: Clinically stable, hypercapnic stage IV COPD, no acute exacerbation; Exclusion: Thorax/lung abnormalities other than COPD, BMI≥35, other conditions resulting in hypercapnia, previously initiated NIPPV, malignant comorbidities, severe HF, unstable angina, severe arrhythmias. | BPAP ST + standard care | [underlined: BPAP]; Models not reported, but all were BPAP machines from these manufacturers: ResMed (Martinsried, Germany), Weinmann (Hamburg, Germany, or Tyco Healthcare (Neubrug, Germany) | 102 Patients aged 62.2±8.6, 36% female | COPD
Köhnlein, 2014^37^ | RCT in Germany and Austria, 10/29/2004 to 07/31/2011 | High ROB | | Standard care | No PAP | 93 Patients aged 64.4±8.0, 40% female | COPD
Marquez-Martin, 2014^38^ | RCT in Spain, 05/2007 to 09/2011 | Moderate ROB | Inclusion: Adults with COPD, clinically stable, chronic RF with hypoxemia. | BPAP ST | [underlined: BPAP]; BiPAP; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 15 Patients aged 69 (64-73) | COPD
Marquez-Martin, 2014^38^ | RCT in Spain, 05/2007 to 09/2011 | Moderate ROB | Inclusion: Adults with COPD, clinically stable, chronic RF with hypoxemia. | Exercise program | No PAP | 14 Patients aged 69 (64-73) | COPD
Marquez-Martin, 2014^38^ | RCT in Spain, 05/2007 to 09/2011 | Moderate ROB | Inclusion: Adults with COPD, clinically stable, chronic RF with hypoxemia. | BPAP ST + exercise program | BPAP + no PAP | 14 Patients aged 69 (64-73) | COPD
Masa, 2000^39^ | Observational Prospective in Spain | Moderate ROB | Inclusion: OHS or kyphoscoliosis; Exclusion: Apnea-hypopnea index >20 events/h. | HMV (volume cycled or pressure cycled) in OHS | [underlined: HMV]; Monal DCC (Taema; Paris, France).; (Not FDA approved); Onyx Plus (Mallinckrodt SEFAM; Nancy, France).; (Not FDA approved) | 22 Patients aged 61±14, 81.8% female | OHS
Masa, 2000^39^ | Observational Prospective in Spain | Moderate ROB | Inclusion: OHS or kyphoscoliosis; Exclusion: Apnea-hypopnea index >20 events/h. | HMV (volume cycled or pressure cycled) in kyphoscoliosis | [underlined: HMV]; Monal DCC (Taema; Paris, France).; (Not FDA approved); Onyx Plus (Mallinckrodt SEFAM; Nancy, France).; (Not FDA approved) | 14 Patients aged 43±20, 50% female | TRD
Masa, 2015^40,^ ^41^ | RCT in Spain, 05/2009 to 03/2013 | Moderate ROB | Inclusion: OHS, no relevant COPD, severe OSA, absence of narcolepsy or restless leg syndrome, correctly executed 30 minute CPAP/NIPPV treatment test; Exclusion: Psychophysical inability to complete questionnaires, severe chronic debilitating illness, severe chronic nasal obstruction. | Mixed: HMV and BPAP mix (all with bilevel pressure with assured volume) | [underlined: HMV/BPAP]; Breas Vivo 40 (General Electric; England); (FDA approved 510(k) clearance); BiPAP AVAPS (Phylips-Respironics; Netherlands); (FDA approved 510(k) clearance); Trilogy 100 (Philips-Respironics; Netherlands); (FDA approved 510(k) clearance); VS Ultra (ResMed; Australia); (FDA approved 510(k) clearance); Monal T50 (Air Liquide; France); (Not FDA approved); Puritian Bennett 560 (Puritan Bennett; USA); (FDA approved 510(k) clearance) | 71 Patients aged 64±11, 65% female | OHS
Masa, 2015^40,^ ^41^ | RCT in Spain, 05/2009 to 03/2013 | Moderate ROB | | CPAP + lifestyle modifications | CPAP NOS | 80 Patients aged 57±13, 47% female | OHS
Masa, 2015^40,^ ^41^ | RCT in Spain, 05/2009 to 03/2013 | Moderate ROB | | Lifestyle modifications | No PAP | 70 Patients aged 60±13, 56% female | OHS
Masa, 2016^42^ | RCT in Spain, 05/2009 to 03/2013 | High ROB | Inclusion: OHS (BMI ≥ 30 kg/m2, no COPD, no NMD, no TRD, no narcooepsy, no restless leg syndrome), stable hypercapnic respiratory failure (daytime awake PaCO2 ≥ 45 mmHg, pH ≥ 7.35 and no clinical worsening in prior 2 months), ability to use NIPPV in 30 minute trial period; Exclusion: Psychophysical inability to complete questionnaires, severe chronic debilitating illness, severe chronic nasal obstruction, lack of informed consent. | BPAP volume assured pressure support ventilation | BPAP volume assured pressure support ventilation | 40 Patients aged 67 [IQR12], 75% female | OHS
Masa, 2016^42^ | RCT in Spain, 05/2009 to 03/2013 | High ROB | | No PAP | No PAP | 46 Patients aged 69 [IQR 15], 83% female | OHS
McEvoy, 2009^43^ | RCT in Australia, 06/30/1998 to 05/15/2004 | Moderate ROB | Inclusion: Age<80 years, severe COPD secondary to smoking, stable hypercapnic ventilatory failure, on LTOT ≥3 months, not currently smoking; Exclusion: significant comorbidities (malignancies, left ventricular heart failure, unstable angina) likely affecting 2 year survival, severe psychiatric disorder impairing ability to comply to NIPPV, BMI>40, evidence of sleep apnea. | BPAP S + Oxygen | BPAP VPAP S mode; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 72 Patients aged 67.2 (IQR 65.3 to 69.1), 31% female | COPD
McEvoy, 2009^43^ | RCT in Australia, 06/30/1998 to 05/15/2004 | Moderate ROB | | Oxygen alone | No PAP | 72 Patients aged 68.8 (IQR 67.1 to 70.5), 39%% female | COPD
Munoz, 2005^44^ | Observational Retrospective in Spain, 1997 to 2001 | Moderate ROB | Inclusion: Treated with non-invasive home volumetric ventilator, followup ≥1 year; Exclusion: BPAP users. | HMV volume assist control ventilation | HMV volume assist/control mode | 45 Patients aged 65.1±12.9, 48.9% female | Mixed (NMD, TRD)
Munoz, 2005^44^ | Observational Retrospective in Spain, 1997 to 2001 | Moderate ROB | Inclusion: Treated with non-invasive home volumetric ventilator, followup ≥1 year; Exclusion: BPAP users. | HMV volume control | HMV volume control mode | 65 Patients aged 60.3 years±14.7 years, 46.2% female | Mixed (NMD, TRD)
Murphy, 2012^45^ | RCT in United Kingdom | Moderate ROB | Inclusion: BMI>40, absence of other identifiable hypoventilation cause; Exclusion: Inability to provide written consent. | BPAP AVAPS | [underlined: BPAP]; BiPAP synchrony; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 25 Patients aged 53±9, 52% female | OHS
Murphy, 2012^45^ | RCT in United Kingdom | Moderate ROB | Inclusion: BMI>40, absence of other identifiable hypoventilation cause; Exclusion: Inability to provide written consent. | BPAP ST | [underlined: BPAP]; BiPAP synchrony; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 25 Patients aged 56±11, 56% female | OHS
Murphy, 2017^46^ | RCT in United Kingdom, 2010 to 2015 | High ROB | Inclusion: Persistent hypercapnia and hypoxemia, >30% sleep time <90% oxygen saturation, arterial pH >7.30 breathing room air; Exclusion: BMI >35, OSA, other RF causes. | BPAP ST + Home oxygen | [underlined: BPAP]; Harmony 2; Philips Respironics; (FDA approved 510(k) clearance); VPAP III STa; ResMed; (FDA approved 510(k) clearance) | 57 Patients aged 66.4±10.2, 51% female | COPD
Murphy, 2017^46^ | RCT in United Kingdom, 2010 to 2015 | High ROB | Inclusion: Persistent hypercapnia and hypoxemia, >30% sleep time <90% oxygen saturation, arterial pH >7.30 breathing room air; Exclusion: BMI >35, OSA, other RF causes. | Home oxygen | No PAP | 59 Patients aged 67.1±9.0, 54% female | COPD
Nauffal, 2002^47^ | Observational Prospective in Spain, 01/1997 to 03/2000 | Moderate ROB | Inclusion: Chronic hypoventilation due to kyphoscoliosis or NMD, moderate to severe restrictive ventilatory pattern, clinically stable. | BPAP NOS in kyphoscoliosis | [underlined: BPAP]; DP-90; Taema (Paris, France); (Not FDA approved) | 35 Patients aged 55.9, 40% female | TRD
Nauffal, 2002^47^ | Observational Prospective in Spain, 01/1997 to 03/2000 | Moderate ROB | Inclusion: Chronic hypoventilation due to kyphoscoliosis or NMD, moderate to severe restrictive ventilatory pattern, clinically stable. | BPAP NOS in neuromuscular diseases | [underlined: BPAP]; DP-90; Taema (Paris, France); (Not FDA approved) | 27 Patients aged 42.5, 48% female | NMD
Oscroft, 2010^48^ | Observational Retrospective in United Kingdom, 01/2000 to 12/2003 | Moderate ROB | Inclusion: COPD diagnosis, smoking history >20 pack years, ventilatory failure with a daytime PaCO2 > 7 kPa with a pH > 7.35 or nocturnal transcutaneous PaCO2 > 9 kPa, hospital admission immediately prior to referral with clinical diagnosis of exacerbation of COPD; Exclusion: Age>80 years, other respiratory disease, BMI>35, significant OSA, tracheostomy, impaired left ventricular function. | BPAP ST started after AECOPD; BPAP ST started in stable patient without exacerbation | [underlined: BPAP]; NIPPY l, 2 or 3; B & D Electromedical (Stratford, United Kingdom); (Not FDA approved) | 31 Patients aged 66±6, 49% female | COPD
Oscroft, 2010^48^ | Observational Retrospective in United Kingdom, 01/2000 to 12/2003 | Moderate ROB | | BPAP ST started after AECOPD; BPAP ST started in stable patient without exacerbation | [underlined: BPAP]; NIPPY l, 2 or 3; B & D Electromedical (Stratford, United Kingdom); (Not FDA approved) | 16 Patients aged 63±7 | COPD
Oscroft, 2010^49^ | RCT in United Kingdom, 07/01/2005 to 09/30/2006 | Moderate ROB | Inclusion: COPD, FEV1<50%, FEV1/FVC<70%, TLC>80%, >20 pack year smoking history, pH 7.35-7.45, PaCO2>7.5 kPa or PtcCo2>9kPa, treated with NIPPV for at least 3 months with compliance at least 4 hours/day, clinical stability (no increased breathlessness, cough or sputum in the prior 4 weeks, no increase in PaCO2 and no decrease in FEV1 since study initiation); Exclusion: >80 years old, other respiratory disease (interstitial lung disease, asthma, bronchiectasis, neuromuscular or restrictive chest wall disorders, left ventricular ejection fraction <40% | NIPPV continue | [underlined: BPAP]; NIPPY 2; B and D Electromedical (Stratford, United Kingdom); (Not FDA approved) | 5 Patients aged 69.2±7.4 | COPD
Oscroft, 2010^49^ | RCT in United Kingdom, 07/01/2005 to 09/30/2006 | Moderate ROB | | NIPPV discontinue (no PAP) | No PAP | 5 Patients aged 58.6±6.3 | COPD
Oscroft, 2014^50^ | RCT in United Kingdom, 09/2007 to 12/2011 | High ROB | Inclusion: COPD diagnosis, smoking history >20 pack years, ventilatory failure with a daytime PaCO2 > 7 kPa with a pH > 7.35 or nocturnal transcutaneous PaCO2 > 9 kPa; Exclusion: Age>80 years, other respiratory disease, BMI>40, significant OSA. | BPAP IVAPS | [underlined: BPAP]; Intelligent volume assured pressure support (iVAPS); ResMed (Bella Vista, Australia; (FDA approved 510(k) clearance) | 20 Patients aged 67.6±7.9, 55% female | COPD
Oscroft, 2014^50^ | RCT in United Kingdom, 09/2007 to 12/2011 | High ROB | | BPAP ST | [underlined: BPAP]; NIPPY 3; B and D Electromedical (Stratford, United Kingdom); (Not FDA approved) | 20 Patients aged 67.4±8.2, 50% female | COPD
Paone, 2014^51^ | Observational Prospective in Italy, 3/2007 and 1/2010 | Low ROB | Inclusion: Acute RF needing NIPPV, clinical stability with symptoms of nocturnal Hypoventilation, FEV1 < 50% predicted, <20% improvement in FEV1 following bronchodilator and a ratio FEV1/FVC < 0.70; Exclusion: Significant comorbidities affecting survival (cancer, left ventricular heart failure, unstable angina), psychiatric disorders potentially affecting ability to undergo NIPPV, other chronic respiratory disease, history of OSA, BMI>40, systemic steroids therapy. | BPAP ST (PSV ST) + Home oxygen | [underlined: BPAP]; Synchrony; Philips Respironics (Andover MA, USA); (FDA approved 510(k) clearance); Neftis; Linde (Munich Germany); (Not FDA approved) | 48 Patients, 56.2% female | COPD
Paone, 2014^51^ | Observational Prospective in Italy, 3/2007 and 1/2010 | Low ROB | | Home oxygen | No PAP | 45 Patients aged 72 (IQR 66-78), 48.9% female | COPD
Perez de Llano, 2005^52^ | Observational in Spain, 03/1995 to 12/2002 | Low ROB | Inclusion: OHS, BMI > 30, PaCO2 ≥ 50 mmHg, FEV1/FVc < 70%, absence of other respiratory disorder such as kyphoscoliosis or diaphragmatic paralysis; Exclusion: <12 months followup | HMV/BPAP mix | [underlined: HMV]; Home 2; Airox (Pau, France); (Not FDA approved); [underlined: BPAP]; DP-90; Taema (Paris, France); (Not FDA approved); PV-102; Breas (Gothenburg, Sweden); (FDA approved 510(k) clearance) | 54 patients aged 56 ± 13, 33.3% female | OHS
Perez de Llano, 2005^52^ | Observational in Spain, 03/1995 to 12/2002 | Low ROB | Inclusion: OHS, BMI > 30, PaCO2 ≥ 50 mmHg, FEV1/FVc < 70%, absence of other respiratory disorder such as kyphoscoliosis or diaphragmatic paralysis; Exclusion: <12 months followup | No PAP | | 15 patients aged 62 years, 66.7% female | OHS
Pinto, 1995^53^ | Observational Prospective in Portugal | High ROB | Inclusion: Consecutive ALS patients with bulbar features; Exclusion: tracheotomised, refusal of attempts to prolong survival. | BPAP NOS | BPAP | 10 Patients aged 60.66, 45% female between both groups | NMD
Pinto, 1995^53^ | Observational Prospective in Portugal | High ROB | Inclusion: Consecutive ALS patients with bulbar features; Exclusion: tracheotomised, refusal of attempts to prolong survival. | No BPAP NOS | No PAP | 10 Patients aged 57.22, 45% female between both groups | NMD
Pinto, 2010^54^ | Observational Prospective in Portugal, 01/2003 to 09/2006 | High ROB | Inclusion: No signs/symptoms of respiratory insufficiency, age 18-75 years; Exclusion: Gastrostomy, cognitive impairment, other significant disorders. | BPAP ST + weekly telemonitoring + standard care | [underlined: BPAP]; Goodknight 425ST bi-level device; Tyco Healthcare Group LP (California, USA); (FDA approved 510(k) clearance) | 20 Patients aged 62±12.90, 31.6% female | NMD
Pinto, 2010^54^ | Observational Prospective in Portugal, 01/2003 to 09/2006 | High ROB | Inclusion: No signs/symptoms of respiratory insufficiency, age 18-75 years; Exclusion: Gastrostomy, cognitive impairment, other significant disorders. | BPAP ST + standard care | [underlined: BPAP]; Goodknight 425ST bi-level device; Tyco Healthcare Group LP (California, USA); (FDA approved 510(k) clearance) | 20 Patients aged 60±10, 30% female | NMD
Piper, 2008^55^ | RCT in Australia | Low ROB | Inclusion: BMI≥30, stable awake compensated RF, absence of significant respiratory, NMD, or other disorder that could account for hypercapnia, no psychiatric illness capable of affecting participation, not currently treated with positive pressure therapy; Exclusion: Oxygen saturation below 80% continuously, acute rise in tcCO2 during episodes of REM sleep, increase in afternoon to morning PaCO2 ≥10mmHg. | BPAP S | BPAP | 18 Patients aged 47±13, 50% female | OHS
Piper, 2008^55^ | RCT in Australia | Low ROB | | CPAP | CPAP | 18 Patients aged 52±17, 22.2% female | OHS
Priou, 2010^56^ | Observational in France, 01/1995 to 12/2006 | Moderate ROB | Inclusions: BMI ≥ 30 kg/m 2 and daytime hypercapnia (PaCO2> 45 mm Hg) in the absence of any other cause of hypoventilation on the basis of clinical examination, chest radiograph, and pulmonary function tests (eg, COPD [FEV 1 to vital capacity ratio, 70%]). | BPAP started in stable hypercapnia | NR | 92 patients aged 59.7 ± 12.9, 41.3% female | OHS
Priou, 2010^56^ | Observational in France, 01/1995 to 12/2006 | Moderate ROB | | BPAP started in acute exacerbation | NR | 38 patients aged 60.7 ± 16.3, 47.4% female | OHS
Salturk, 2015^57^ | Observational Retrospective in Turkey, 01/2011 to 01/2012 | Low ROB | Inclusion: Received NIPPV in ICU/home at least 4 hour/day, attending 1 month and 1 year followup; Exclusion: Disabled or unwilling to walk, clinical airway infection, current exacerbations, unstable cardiac arrhythmia. | BPAP ST COPD | BPAP COPD | 37 Patients aged 65±10, 8.1% female | COPD
Salturk, 2015^57^ | Observational Retrospective in Turkey, 01/2011 to 01/2012 | Low ROB | | BPAP ST OHS | BPAP OHS | 34 Patients aged 65±8, 50% female | OHS
Salturk, 2015^57^ | Observational Retrospective in Turkey, 01/2011 to 01/2012 | Low ROB | | BPAP ST Kyphoscoliosis | BPAP | 20 Patients aged 46±10, 45% female | TRD
Salturk, 2015^57^ | Observational Retrospective in Turkey, 01/2011 to 01/2012 | Low ROB | | BPAP ST Diffuse Parenchymal Lung Disease | BPAP | 14 Patients aged 62±12, 21.4% female | Other
Sancho, 2014^58^ | Observational Retrospective in Spain/France, 03/2003 to 12/2007 | Low ROB | Inclusion: Indication for NIPPV from presence of hypoventilation symptoms; Exclusion: Presence of previous pulmonary/airway disease, rapidly progressing disease with survival expectancy <1 month, severe frontotemporal dementia, NIPPV tolerance <4 consecutive hour/night. | HMV (volume assist control ventilation) | [underlined: HMV]; PV 501; Breas Medical (Molndal, Sweden); (FDA approved 510(k) clearance); Legendair; Airox (Pau, France); (Not FDA approved) | 62 Patients aged 62.21±8.81, 54.8% female | NMD
Sancho, 2014^58^ | Observational Retrospective in Spain/France, 03/2003 to 12/2007 | Low ROB | | BPAP ST | [underlined: BPAP]; VPAP-III or VPAP-IV plus automatic ventilatory signal analysis (Reslink); Resmed (Sydney, Australia); (FDA approved 510(k) clearance) | 82 Patients aged 63.80±110.65, 24.4% female | NMD
Sancho, 2017^59^ | Observational Prospective in Spain, 01/1/2013 to 12/31/2015 | High ROB | Inclusion: ALS (Escorial criteria), hospital admission; Exclusion: lung disease, <1 year life expectancy, NIV use <4 consecutive hours/night, slow disease progression (>3 yrs), severe frontotemporal dementia | HMV (volume assist control ventilation) in no/mild bulbar | [underlined: HMV]; Vivo 50; Breas Medical (Molndal, Sweden); (FDA approved 510(k) clearance); Trilogy 100; Philips Respironics (Madrid, Spain); (FDA approved 510(k) clearance) | 105 patients aged 64.05±9.11, 53% female | NMD
Sancho, 2017^59^ | Observational Prospective in Spain, 01/1/2013 to 12/31/2015 | High ROB | | HMV (volume assist control ventilation) in moderate/severe bulbar | [underlined: HMV]; Vivo 50; Breas Medical (Molndal, Sweden); (FDA approved 510(k) clearance); Trilogy 100; Philips Respironics (Madrid, Spain); (FDA approved 510(k) clearance) | 15 patients aged 64.05±9.11, 53% female | NMD
Sancho, 2017^59^ | Observational Prospective in Spain, 01/1/2013 to 12/31/2015 | High ROB | | No device in no/mild bulbar | No PAP | 14 patients aged 66.05±10.27, 70% female | NMD
Sancho, 2017^59^ | Observational Prospective in Spain, 01/1/2013 to 12/31/2015 | High ROB | | No device in moderate/severe bulbar | No PAP | 6 patients aged 66.05±10.27, 70% female | NMD
Sanjuan-López, 2014^60^ | Observational Retrospective in Spain, 01/01/2000 to 12/31/2010 | High ROB | Inclusion: Definitive ALS diagnosis by neurologist; Exclusion: Neuromuscular processes other than ALS, treatment in social welfare palliative center. | HMV (PSV or BPAP ST) started after outpatient pulmonary evaluation | [underlined: HMV]; VS ultra and VS III; ResMed; (FDA approved 510(k) clearance) | 26 Patients aged 67.3±10.8, 50% female | NMD
Sanjuan-López, 2014^60^ | Observational Retrospective in Spain, 01/01/2000 to 12/31/2010 | High ROB | Inclusion: Definitive ALS diagnosis by neurologist; Exclusion: Neuromuscular processes other than ALS, treatment in social welfare palliative center. | HMV (PSV or BPAP ST) started in an emergency situation without prior outpatient pulmonary evaluation | [underlined: HMV]; VS ultra and VS III; ResMed; (FDA approved 510(k) clearance) | 11 Patients aged 67.3±10.8, 50% female | NMD
Schonhofer, 2001^61^ | Observational Prospective in Germany | High ROB | Inclusion: Chronic respiratory failure from thoracic disease & hypercapnic, clinically stable, no significant difference in blood gas analysis parameters; Exclusion: Rapidly progressive NMD, OHS, COPD, acute RF, severe acidosis | Mixed: HMV (volume assist control ventilation) with change to BPAP ST if not tolerated | [underlined: HMV]; Drager EV 800 (Drager; Lubeck, Germany); (Not FDA approved); PLV 100 (Respironics; Murrysville, USA); (FDA approved 510(k) clearance); [underlined: BPAP]; BP-T (Respironics Inc.; Murrysville, USA); (FDA approved 510(k) clearance) | 10 Patients aged 53.5±8.2, 50% female | TRD
Schonhofer, 2001^61^ | Observational Prospective in Germany | High ROB | | Standard care without HMV | No HMV | 10 Patients aged 52.2±9.5, 50% female | TRD
Sin, 2007^62^ | RCT in Canada, | Moderate ROB | Inclusion: Diagnosis of COPD, age≥40 years, >10 pack year smoking history; Exclusion: Comorbidities making survival <6 months unlikely, clinical history of left ventricular heart failure, apnea-hypopnea index >20 | BPAP NOS + standard care | [underlined: BPAP]; VPAP II, ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 11 Patients aged 64.1±10.6, 64% female | COPD
Sin, 2007^62^ | RCT in Canada, | Moderate ROB | | Sham BPAP (CPAP 4) | [underlined: Sham Device]; S7Elite; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 10 Patients aged 66.6±9.7, 40% female | COPD
Sivori, 2007^63^ | Observational Prospective in Argentina, 12/1999 to 12/2004 | Moderate ROB | Inclusion: Diagnosis of ALS. | BPAP NOS + riluzole | BPAP + riluzole | 18 Patients aged 53±15.46, 44.4% female | NMD
Sivori, 2007^63^ | Observational Prospective in Argentina, 12/1999 to 12/2004 | Moderate ROB | Inclusion: Diagnosis of ALS. | BPAP NOS | BPAP | 11 Patients aged 56.4±15.5, 36.4% female | NMD
Sivori, 2007^63^ | Observational Prospective in Argentina, 12/1999 to 12/2004 | Moderate ROB | Inclusion: Diagnosis of ALS. | no BPAP, no riluzole | No PAP | 42 Patients aged 52.3±11.4, 31% female | NMD
Sivori, 2007^63^ | Observational Prospective in Argentina, 12/1999 to 12/2004 | Moderate ROB | Inclusion: Diagnosis of ALS. | Riluzole | Riluzole | 26 Patients aged 57.4±12.6, 38.5% female | NMD
Struik, 2014^64^ | RCT in the Netherlands, 12/01/2007 to 07/01/2012 | Moderate ROB | Inclusion: COPD (GOLD III/IV), >48 hours independence from ventilator support for acute RF, hypercapnia (PaCO2 >6.0 kPa) daytime at rest | BPAP ST | [underlined: BPAP]; BiPAP Synchrony; Respironics (Murrysville, USA); (FDA approved 510(k) clearance) | 101 Patients aged 63.92±8.6, 59% female | COPD
Struik, 2014^64^ | RCT in the Netherlands, 12/01/2007 to 07/01/2012 | Moderate ROB | Inclusion: COPD (GOLD III/IV), >48 hours independence from ventilator support for acute RF, hypercapnia (PaCO2 >6.0 kPa) daytime at rest | Standard care | No PAP | 100 Patients aged 63.5±7.9, 58% female | COPD
Tsolaki, 2008^65^ | Observational Prospective in Greece, 09/2005 to 12/2006 | High ROB | Inclusion: Age ≤75 years, smoking history >20 pack years; Exclusion: Significant comorbidities (OSA, OHS, RF from disease other than COPD), important concomitant chronic systemic disorders, poor ventilator compliance, apnea-hypopnea index ≥10 episodes/hr. | BPAP ST | [underlined: BPAP]; VPAP III ST; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 24 Patients aged 65.2±8.9, 29.2% female | COPD
Tsolaki, 2008^65^ | Observational Prospective in Greece, 09/2005 to 12/2006 | High ROB | | Standard care | No PAP | 22 Patients aged 68.9±5.6, 36.4% female | COPD
Tsolaki, 2011^66^ | Observational in Greece, dates not reported | Low ROB | Inclusion: symptoms of nocturnal hypoventilation (fatigue, dyspnea, morning headaches) combined with daytime hypercapnia (PaCO2 ≥45mmHg for TRD and NMD, PaCO2 ≥50mmHg for COPD).; For OHS: BMI> 30, PaCO2 >45mmHg, PaO2 <70mmHg) in the absence of other diseases, persistent hypoventilation despite overnight trial of CPAP.; Exclusion: Apnea-hypopnea index >10/h (except patients with OHS), acute respiratory failure (pH < 7.35 and symptoms such as increasing cough, purulent sputum, need for antibiotics) or patients with an exacerbation during 4 weeks preceding, respiratory support other than NIV, poor compliance with NIV (i.e. mean use < 4 h/day) at the first follow-up visit | BPAP ST in COPD | [underlined: BPAP]; VPAP III ST; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 35 patients aged 67.1 ± 9.0, 20.0% female | COPD
Tsolaki, 2011^66^ | Observational in Greece, dates not reported | Low ROB | | BPAP ST in TRD | [underlined: BPAP]; VPAP III ST; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 17 patients aged 65.8 ± 7.8, 35.3% female | TRD
Tsolaki, 2011^66^ | Observational in Greece, dates not reported | Low ROB | | BPAP ST in NMD | [underlined: BPAP]; VPAP III ST; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 11 patients aged 62.8 ± 11.0, 63.6% female | NMD
Tsolaki, 2011^66^ | Observational in Greece, dates not reported | Low ROB | | BPAP ST in OHS | [underlined: BPAP]; VPAP III ST; ResMed (Sydney, Australia); (FDA approved 510(k) clearance) | 28 patients aged 63.0 ± 9.9, 35.7% female | OHS
Vasquez, 2017^67^ | Observational Retrospective in USA, 01/1/2009 to 10/31/2014 | Moderate ROB | Inclusion: At least 2 COPD claims, age ≥40 years, continuous enrollment 12 month prior & 6 months after claim | BPAP NOS | BPAP | 9,156 Patients, 35.8% female | COPD
Vasquez, 2017^67^ | Observational Retrospective in USA, 01/1/2009 to 10/31/2014 | Moderate ROB | Inclusion: At least 2 COPD claims, age ≥40 years, continuous enrollment 12 month prior & 6 months after claim | CPAP NOS | CPAP | 39,385 Patients, 45.1% female | COPD
Vasquez, 2017^67^ | Observational Retrospective in USA, 01/1/2009 to 10/31/2014 | Moderate ROB | Inclusion: At least 2 COPD claims, age ≥40 years, continuous enrollment 12 month prior & 6 months after claim | HMV NOS | HMV | 315 Patients, 48.9% female | COPD
Vitacca, 2017^68^ | Observational Retrospective in Italy, 2008-2013 | Moderate ROB | Inclusion: ALS NOS admitted to hospital, NIPPV use; Exclusion: dementia confirmed by Mini-Mental State Examination score <20, refusal of NIPPV | HMV/BPAP mix started in FVC≥ 80% (early) | HMV/BPAP mix | 65 patients aged 62.62±11.34, 30.77% female | NMD
Vitacca, 2017^68^ | Observational Retrospective in Italy, 2008-2013 | Moderate ROB | Inclusion: ALS NOS admitted to hospital, NIPPV use; Exclusion: dementia confirmed by Mini-Mental State Examination score <20, refusal of NIPPV | HMV/BPAP mix started in FVC <80% (late) | HMV/BPAP mix | 129 patients aged 64.66±11.33, 48.06% female | NMD
Windisch, 2006^69^ | Observational in Germany | Moderate ROB | Inclusion: Stable disease hospitalized for establishing NIPPV, matched controls; Exclusion: Acute RF, signs of respiratory infection, intubated or tracheotomised previously in life, established on other ventilatory support prior to admission | HMV (pressure controlled ventilation) | [underlined: HMV]; PV401; Breas Medical AB (Moelnlycke, Sweden); (FDA approved 510(k) clearance) | 6 Patients aged 55.2±10.0, 16.7% female | COPD
Windisch, 2006^69^ | Observational in Germany | Moderate ROB | | HMV (pressure controlled ventilation) | [underlined: HMV]; PV401; Breas Medical AB (Moelnlycke, Sweden); (FDA approved 510(k) clearance) | 6 Patients aged 61.7±11.3, 33% female | Mixed (TRD+OHS)
Zhou, 2017^70^ | RCT in China, 10/01/2015 to 05/31/2016 | High ROB | Inclusion: Clinically stable, stage III/IV flow limitation & chronic hypercapnic, age > 40 years; Exclusion: Abnormalities of lung/thorax other than COPD, previously treated on NIPPV, OSA, severe HF, severe arrhythmias, unstable angina, malignant comorbidities, COPD with OSA overlap syndrome, impairments that could affect ability for followup. | BPAP ST | [underlined: BPAP]; Flexo ST 30 NIV; Curative Co. (SuZhou, China); (Not FDA approved) | 57 Patients aged 66.91±7.1, 36.8% female | COPD
Zhou, 2017^70^ | RCT in China, 10/01/2015 to 05/31/2016 | High ROB | | Standard care | No PAP | 58 Patients aged 68.47±6.57, 39.7% female | COPD

Note: ± denotes standard deviation.

AECOPD: acute exacerbation of chronic obstructive pulmonary disease, ALS: amyotrophic lateral sclerosis, AVAPS: average volume assured pressure support, BMI: Body Mass Index, BPAP: Bilevel Positive Airway Pressure, CHRF: chronic hypercapnic respiratory failure, COPD: chronic obstructive pulmonary disease, CPAP: Continuous Positive Airway Pressure, FDA: Food and Drug Administration, FEV1: Forced expiratory volume in one second, FVC: Forced vital capacity, HF: heart failure, HMV: Home Mechanical Ventilation, ICU: Intensive Care Unit, IQR: Interquartile range, kPa: kilopascal, LTOT: Long term oxygen, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive positive pressure ventilation, NMD: Neuromuscular Disease, NOS: Not otherwise Specified, OHS: Obesity hypoventilation syndrome, OSA: Obstructive sleep apnea, PaCO2: partial pressure of arterial carbon dioxide, PAP: positive airway pressure, pH: potential of hydrogen, PSV: Pressure support ventilation, RCT: randomized controlled trial, REM: rapid eye movement, ROB: risk of bias, RF: Respiratory Failure, S: spontaneous mode, SE: standard error, SpO2: Blood oxygen saturation level, ST: spontaneous/timed breath mode, tcCO2/PtCO2: transcutaneous carbon dioxide, TRD: Thoracic Restrictive Disorder, TWD: Thoracic Wall Diseases, USA: United States of America