# Appendix C Excluded Studies

1 [Guidelines for home mechanical ventilation. Swiss Association for the control of Tuberculosis and Lung Diseases (ASTP). Swiss Society of Pneumology (SSP)]. Schweizerische Medizinische Wochenschrift Journal Suisse de Medecine. 1996 Dec 28;126(51-52):2245–50. PMID: 9011937. [Foreign language study].9011937
2 [Guidelines for indications and implementation of intermittent self-ventilation. German Society of Pneumology]. Pneumologie. 1994 May;48: Suppl 1:331–3. PMID: 8084877. [Foreign language study].8084877
3 [Guidelines for mechanical home ventilation. SVTL (Swiss Society against Tuberculosis and Lung Diseases). SGP (Swiss Society for Pneumology)]. Schweizerische Medizinische Wochenschrift Journal Suisse de Medecine. 1996 Dec 14;126(50):2191–6. PMID: 9005530. [Foreign language study].9005530
4 [Searching the literature for non-invasive positive pressure ventilation for neuromuscular diseases]. Revue des Maladies Respiratoires. 2006 Nov;23(5 Pt 4):14S1–S3. PMID: 17151546. [Foreign language study].17151546
5 A trial comparing artificial noses and heat exchanges during assisted ventilation by tracheotomy in the home. [French]. Revue des Maladies Respiratoires. 1993;10(5):437–44. PMID: 23344441. [Published before 1995].8256030
6 AARC (American Association for Respiratory Care) clinical practice guideline. Long-term invasive mechanical ventilation in the home. [Reprint in Respir Care. 2007 Aug;52(8):1056-62; PMID: 17715560]. Respiratory Care. 1995 Dec;40(12):1313–20. PMID: 10153257. [Irrelevant intervention (or time frame)].10153257
7 Aarrestad S, Tollefsen E, Kleiven AL, . Validity of transcutaneous PCO<inf>2</inf> in monitoring chronic hypoventilation treated with non-invasive ventilation. Respiratory Medicine. 2016 01 Mar;112:112–8. PMID: 608329726. [Irrelevant study design].26874895
8 Abrahams Z, Simpson J. Pilot study reviewing patients on domiciliary non-invasive ventilation (NIV) in Tower Hamlets. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780337. [Abstract/conference proceeding].
9 Abroug F, Ouanes-Besbes L, Hammouda Z, . Noninvasive ventilation with helium-oxygen mixture in hypercapnic COPD exacerbation: aggregate meta-analysis of randomized controlled trials. Annals of Intensive Care. 2017 01 Dec;7 (1) (no pagination)(59). PMID: 616822298. [Irrelevant setting/location].
10 Achard J, Alquier P, Dumont AM. [Nine-year study of home assisted ventilation in cases of severe respiratory handicap (author’s transl)]. Revue Francaise des Maladies Respiratoires. 1979 JulAug;7(4):424–6. PMID: 398568. [Published before 1995].398568
11 Ackrivo J, Hansen-Flaschen J, Wileyto EP, . Baseline risk factors for use of non-invasive ventilation in a cohort of patients with amyotrophic lateral sclerosis. Respirology. 2017 November;22 (Supplement 3):44. PMID: 619967492. [Abstract/conference proceeding].
12 Ackrivo J, Wileyto E, Elman L, . Baseline predictors of noninvasive ventilation use in amyotrophic lateral sclerosis. Chest. 2017 October;152 (4 Supplement 1):A945. PMID: 619297734. [Abstract/conference proceeding].
13 Adams AB, Whitman J, Marcy T. Surveys of long-term ventilatory support in Minnesota: 1986 and 1992. Chest. 1993 May;103(5):1463–9. PMID: 8486028. [Published before 1995].8486028
14 Adler D, Perrig S, Takahashi H, . Polysomnography in stable COPD under non-invasive ventilation to reduce patient-ventilator asynchrony and morning breathlessness. Sleep & Breathing. 2012 Dec;16(4):1081–90. PMID: 22051930. [Irrelevant comparison or no comparison].22051930
15 Agarwal S, Vaughan M, Wharton C, . Routes of domiciliary non-invasive ventilation (NIV) set-up. Thorax. 2012 December;67:A163. PMID: 71126402. [Abstract/conference proceeding].
16 Aigner K, Burghuber OC, Hartl S, . Indication for long-term oxygen therapy and home mechanical ventilation. Consensus of the Austrian Society for Lung Disease and Tuberculosis. [German]. Atemwegs- und Lungenkrankheiten. 2001;27(2):66–73. PMID: 32184989. [Foreign language study].
17 Alahmadi T, Zielinski D, Troini R, . Experience with a province wide home ventilation program for patients with duchenne muscular dystrophy. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2013;187(no pagination). PMID: 71985257. [Abstract/conference proceeding].
18 Albert SM, Whitaker A, Rabkin JG, . Medical and supportive care among people with ALS in the months before death or tracheostomy. Journal of Pain & Symptom Management. 2009 Oct;38(4):546–53. PMID: 19540088. [Irrelevant comparison or no comparison].19540088
19 Alhelali RA, McNabb SJN, Memish ZA. Evaluation of home respiratory therapy delivered to patients in the Ministry of Health’s Home Medical Program (HMP) and administered through the Madinah HMP Center, Kingdom of Saudi Arabia, 2013. Journal of Epidemiology and Global Health. 2016 Mar;6(1):19–27. PMID: 26304013. [Irrelevant comparison or no comparison].26304013
20 Ali MS, Talwar D, Singh M. Nocturnal noninvasive ventilation improves muscle strength in stable COPD patients with respiratory failure. Thorax. 2012 December;67:A165. PMID: 71126406. [Abstract/conference proceeding].
21 Ali S, Kabir Z. Domiciliary non-invasive ventilation and the quality of life outcome of patients suffering from chronic respiratory failure. Irish Medical Journal. 2007 Jan;100(1):336–8. PMID: 17380925. [Irrelevant study design].17380925
22 Alison Galbraith AfHR, Quality CHA, Harvard School of Public Health HPHC. Evaluating Sequential Strategies to Reduce Readmission in a Diverse Population. 2011 October. PMID: NCT01619098. [Irrelevant patient (age, medical condition)].
23 Almarakbi WA, Fawzi HM, Alhashemi JA. Effects of four intraoperative ventilatory strategies on respiratory compliance and gas exchange during laparoscopic gastric banding in obese patients. British Journal of Anaesthesia. 2009 Jun;102(6):862–8. PMID: 19403595. [Irrelevant setting/location].19403595
24 Altinoz H, Adiguzel N, Salturk C, . May the obesity cause a better prognosis for domiciliary NIV prescribed COPD patients? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105998. [Abstract/conference proceeding].
25 Altinoz H, Adiguzel N, Salturk C, . Obesity might be a good prognosis factor for COPD patients using domiciliary noninvasive mechanical ventilation. International Journal of Copd. 2016;11:1895–901. PMID: 27578969. [Unclear device].27578969
26 Amado-Rodriguez L, Bernal T, Lopez-Alonso I, . Impact of initial ventilatory strategy in hematological patients with acute respiratory failure: A systematic review and meta-analysis. Critical Care Medicine. 2016 01 Jul;44(7):1406–13. PMID: 608645200. [Irrelevant patient (age, medical condition)].26909503
27 Ambrosino N, Vitacca M, Dreher M, . Tele-monitoring of ventilator-dependent patients: a European Respiratory Society Statement. European Respiratory Journal. 2016 Sep;48(3):648–63. PMID: 27390283. [Irrelevant intervention (or time frame)].27390283
28 Andersen MP, Laub M, Biering-Sorensen F. Phrenic pacing compared with mechanical ventilation. Spinal Cord Series and Cases. 2017;3:17022. PMID: 28503328. [Irrelevant patient (age, medical condition)].28503328
29 Ando M, Suetsugu S, Matsumoto S, . [Long-term outcome of patients treated by home mechanical ventilation]. Nihon Kokyuki Gakkai Zasshi. 2003 Nov;41(11):797–802. PMID: 14661551. [Foreign language study].14661551
30 Andreu AL, Chiner E, Sancho-Chust JN, . Effect of an ambulatory diagnostic and treatment programme in patients with sleep apnoea. European Respiratory Journal. 2012 Feb;39(2):305–12. PMID: 21719490. [Irrelevant patient (age, medical condition)].21719490
31 Ankjaergaard KL, Rasmussen DB, Schwaner SH, . COPD: Mortality and Readmissions in Relation to Number of Admissions with Noninvasive Ventilation. Copd: Journal of Chronic Obstructive Pulmonary Disease. 2017 Feb;14(1):30–6. PMID: 27723369. [Irrelevant intervention (or time frame)].27723369
32 Ankjaergaard KL, Tonnesen P, Laursen LC, . Home Non Invasive Ventilation (NIV) treatment for COPD patients with a history of NIV-treated exacerbation; a randomized, controlled, multi-center study. BMC Pulmonary Medicine. 2016 Feb 12;16:32. PMID: 26867542. [Irrelevant outcome].26867542
33 Ankjaergaartd K, Maibom S, Wilcke JT. Home NIV for patients with stable COPD. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71924009. [Abstract/conference proceeding].
34 Ansari Z, Sahal A, Sharma P, . Does relationship exist between domiciliary non-invasive ventilation (NIV) and frequency of hospital admissions in patients with chronic type 2respiratory failure? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849063. [Abstract/conference proceeding].
35 Ansari Z, Sahal A, Sharma P, . Review of mortality in patients on domiciliary non-invasive ventilation for type 2 respiratory failure. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849064. [Abstract/conference proceeding].
36 Anton A, Guell R. Home mechanical ventilation in COPD: Do we know when and how to use it? Chest. 2000;118(6):1525–6. PMID: 32001771. [Irrelevant study design].11115429
37 Anton A, Tarrega J, Giner J, . Acute physiologic effects of nasal and full-face masks during noninvasive positive-pressure ventilation in patients with acute exacerbations of chronic obstructive pulmonary disease. Respiratory Care. 2003 Oct;48(10):922–5. PMID: 14525628. [Irrelevant setting/location].14525628
38 Antoniadou M, Siopi D, Nena E, . Sleep-disordered breathing in patients with inherited neuromuscular diseases. Effect of non-invasive ventilation during sleep: A single center experience. Sleep Medicine. 2017 December;40 (Supplement 1):e308–e9. PMID: 620788717. [Abstract/conference proceeding].
39 Araujo D, Redondo M, Sucena M, . Effect of non-invasive mechanical ventilation on exacerbations in patients with stable COPD: A 4 year cohort study with one year follow-up. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105978. [Abstract/conference proceeding].
40 Archangelidi O, Simmonds NJ, Carr SB, . A national study of non-invasive ventilation and clinical outcomes in cystic fibrosis. Thorax. 2017 December;72 (Supplement 3):A219–A20. PMID: 619738966. [Abstract/conference proceeding].
41 Argent AC, Biban P. What’s new on NIV in the PICU: Does everyone in respiratory failure require endotracheal intubation? Intensive Care Medicine. 2014 June;40(6):880–4. PMID: 53094050. [Irrelevant study design].24711087
42 Armstrong A, Ross J, Pieri-Davies S. Development and implementation of standard carer training guidelines for the care of long term ventilated patients in the community. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105624. [Irrelevant study design].
43 Assistance Publique - Hôpitaux de Paris AFclM. Efficacy and Tolerance of Early Launching of Nocturnal Non Invasive. 2010 October. PMID: NCT01225614. [Irrelevant patient (age, medical condition)].
44 Association Nationale pour les Traitements AD, les Innovations et la R. Assist Control Versus Pressure Support Modes for Domiciliary Noninvasive Ventilation in Chronic Respiratory Failure. 2006 January. PMID: NCT00189527. [Completed Clinical Trial].
45 Associazione Riabilitatori Insufficienza R. Effects of Home-based Pulmonary Rehabilitation in Patients With Severe or Very Severe Chronic Obstructive Pulmonary Disease (COPD). 2010 September. PMID: NCT01198288. [Irrelevant intervention (or time frame)].
46 Atkeson AD, Persaud R, RoyChoudhury A, . Patient-ventilator asynchrony in Amyotrophic Lateral Sclerosis (ALS) patients beginning Nocturnal Non Invasive Ventilation (NNIV) for FVC. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2011;183(1 MeetingAbstracts). PMID: 70849583. [Abstract/conference proceeding].
47 Atkeson AD, RoyChoudhury A, Harrington-Moroney G, . Patient-ventilator asynchrony with nocturnal noninvasive ventilation in ALS. Neurology. 2011 Aug 09;77(6):549–55. PMID: 21795658. [Irrelevant outcome].21795658
48 Aurora RN, Chowdhuri S, Ramar K, . The treatment of central sleep apnea syndromes in adults: practice parameters with an evidence-based literature review and meta-analyses. Sleep. 2012;35(1):17–40. [Irrelevant patient (age, medical condition)].22215916
49 Aurora RNC, S. Ramar KB, S. R. Casey KRL, . The treatment of central sleep apnea syndromes in adults: practice parameters with an evidence-based literature review and meta-analyses. Sleep. 2012(1):17–40. doi: 10.5665/sleep.1580. PMID: 2221591622215916. [Irrelevant patient (age, medical condition)].
50 Australian NZICRC, Intensive Care Foundation A. TEAM: Trial of Early Activity and Mobilization. 2012 July. PMID: NCT01674608. [Irrelevant patient (age, medical condition)].
51 Avdeev S, Baimakanova G, Krasovsky S, . Home non-invasive ventilation (HNIV) improves survival in hypercapnic patients with cystic fibrosis. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923941. [Abstract/conference proceeding].
52 Ayachi J, Khedher A, Ben Jazia R, . Outcome and prevalence of sleep breathing disorders (SBD) after an acute exacerbation of obesity-hypoventilation syndrome AE/OHS. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614770522. [Abstract/conference proceeding].
53 Bach JR, Desrosiers AM, Litalien C. The support of respiratory muscles in restrictive respiratory failure of neuromuscular origin to prevent tracheostomy: A new paradigm. [French]. Canadian Journal of Respiratory Therapy. 2011;47(3):13–23. PMID: 364632157. [Foreign language study].
54 Bach JR, Gonçalves MR, Hamdani I, . Extubation of patients with neuromuscular weakness: a new management paradigm. Chest. 2010;137(5):1033–9. [Irrelevant outcome].20040608
55 Bach JR, Intintola P, Alba AS, . The ventilator-assisted individual: cost analysis of institutionalization vs rehabilitation and in-home management. Chest. 1992;101(1):26–30. [Published before 1995].1729079
56 Bach JR, Rajaraman R, Ballanger F, . Neuromuscular ventilatory insufficiency: effect of home mechanical ventilator use v oxygen therapy on pneumonia and hospitalization rates. American Journal of Physical Medicine & Rehabilitation. 1998 Jan-Feb;77(1):8–19. PMID: 9482374. [Irrelevant intervention (or time frame)].9482374
57 Bach JR, Sinquee DM, Saporito LR, . Efficacy of mechanical insufflation-exsufflation in extubating unweanable subjects with restrictive pulmonary disorders. Respiratory Care; 2015. [Irrelevant outcome].
58 Bach JR, Tran J, Durante S. Cost and physician effort analysis of invasive vs. noninvasive respiratory management of Duchenne muscular dystrophy. American Journal of Physical Medicine & Rehabilitation. 2015 Jun;94(6):474–82. PMID: 25741618. [Irrelevant intervention (or time frame)].25741618
59 Bach JR. Amyotrophic lateral sclerosis: Communication status and survival with ventilatory support. American Journal of Physical Medicine and Rehabilitation. 1993;72(6):343–9. PMID: 24018906. [Published before 1995].8260126
60 Bach JR. Amyotrophic lateral sclerosis: prolongation of life by noninvasive respiratory AIDS. Chest. 2002 Jul;122(1):92–8. PMID: 12114343. [Irrelevant intervention (or time frame)].12114343
61 Bakke SA, Botker MT, Riddervold IS, . Continuous positive airway pressure and noninvasive ventilation in prehospital treatment of patients with acute respiratory failure: a systematic review of controlled studies. Scandinavian Journal of Trauma, Resuscitation & Emergency Medicine. 2014 Nov 22;22:69. PMID: 25416493. [Irrelevant setting/location].25416493
62 Balami JS, Packham SM, Gosney MA. Non-invasive ventilation for respiratory failure due to acute exacerbations of chronic obstructive pulmonary disease in older patients. Age & Ageing. 2006 Jan;35(1):75–9. PMID: 16364938. [Abstract/conference proceeding].16364938
63 Baldwin-Myers AS, Oppenheimer EA. Quality of life and quality of care data from a 7-year pilot project for home ventilator patients. Journal of Ambulatory Care Management. 1996 Jan;19(1):46–59. PMID: 10154369. [Irrelevant patient (age, medical condition)].10154369
64 Ballard E, Grey N, Jungbluth H, . Unplanned respiratory crises requiring ventilation in Duchenne muscular dystrophy (DMD) patients can be reduced by timely respiratory review and care coordination at the age of transition. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71924011. [Abstract/conference proceeding].
65 Ballerin L. Gold update - Italy 2007/2008. [Italian]. Rassegna di Patologia dell’Apparato Respiratorio. 2008 October;23(5):269–81. PMID: 354150761. [Foreign language study].
66 Barbe F, Quera-Salva MA, De Lattre J, . Long-term effects of nasal-intermittent positive-pressure ventilation on pulmonary function and sleep architecture in patients with neuromuscular diseases. Chest. 1996;110(5):1179–83. PMID: 26380469. [Irrelevant study design].8915217
67 Barle H, Soderberg P, Haegerstrand C, . Bi-level positive airway pressure ventilation reduces the oxygen cost of breathing in long-standing post-polio patients on invasive home mechanical ventilation. Acta Anaesthesiologica Scandinavica. 2005 Feb;49(2):197–202. PMID: 15715621. [Irrelevant patient (age, medical condition)].15715621
68 Barroso LC, Borge JH, Garcia MCG, . Predictors of readmission in patients on home mechanical ventilation (HMV). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923929. [Abstract/conference proceeding].
69 Battisti A, Tassaux D, Bassin D, . Automatic adjustment of noninvasive pressure support with a bilevel home ventilator in patients with acute respiratory failure: a feasibility study. Intensive Care Medicine. 2007 Apr;33(4):632–8. PMID: 17323049. [Irrelevant setting/location].17323049
70 Bauman K, Kurili A, Peploski J, . Home-based diagnosis of nocturnal hypoventilation in neuromuscular disorders. Chest. Conference: CHEST. 2011;140(4 MEETING ABSTRACT). PMID: 70635241. [Abstract/conference proceeding].
71 Baydur A, Layne E, Aral H, . Long term non-invasive ventilation in the community for patients with musculoskeletal disorders: 46 year experience and review. Thorax. 2000 Jan;55(1):4–11. PMID: 10607795. [Irrelevant comparison or no comparison].10607795
72 Bayside Health NH, Medical Research Council A, Monash University CFFA. Non-invasive Ventilation and Oxygen Therapy in Cystic Fibrosis Patients With Nocturnal Oxygen Desaturation. 2003 March. PMID: NCT00157183. [Completed Clinical Trial].
73 Becker EA, Hoerr CA, Wiles KS, . Utilizing Respiratory Therapists to Reduce Costs of Care. Respiratory Care. 2018 Jan;63(1):102–17. PMID: 29184048. [Irrelevant study design].29184048
74 Becker S, Prange T. [Pulmarca Box. Is artificial respiration with continuous negative pressure (CNP) still current today?]. Kinderkrankenschwester. 2001 Aug;20(8):339–42. PMID: 14584176. [Foreign language study].14584176
75 Beesley V, Molloy H, Elliott MW, . Non-invasive ventilation (NIV) in Duchenne muscular dystrophy: A review of 17 years of practice. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614778123. [Abstract/conference proceeding].
76 Belfast Health SCT, Queen’s University B. pRotective vEntilation With Veno-venouS Lung assisT in Respiratory Failure. 2016 March. PMID: NCT02654327. [Irrelevant patient (age, medical condition)].
77 Bellone A, Spagnolatti L, Massobrio M, . Short-term effects of expiration under positive pressure in patients with acute exacerbation of chronic obstructive pulmonary disease and mild acidosis requiring non-invasive positive pressure ventilation. Intensive Care Medicine. 2002 May;28(5):581–5. PMID: 12029406. [Irrelevant setting/location].12029406
78 Ben Saida I, Zarrougui W, Khedher A, . Clinical characteristics of patients with late onset pompe’s disease requiring mechanical ventilation in the long term. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044162. [Abstract/conference proceeding].
79 Beng Leong L, Ming NW, Feng LW. High flow nasal cannula oxygen versus non-invasive ventilation in acute respiratory failure? A systematic analysis of available literature. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044542. [Abstract/conference proceeding].
80 Bennett JA, Cooper BG, Watson L, . Domiciliary non invasive positive pressure ventilation in a single health district. Thorax. 1999;54(SUPPL. 3). [Abstract/conference proceeding].
81 Bento J, Goncalves M, Silva N, . [Indications and compliance of home mechanical insufflation-exsufflation in patients with neuromuscular diseases]. Archivos de Bronconeumologia. 2010 Aug;46(8):420–5. PMID: 20576340. [Foreign language study].20576340
82 Berg G, Delaive K, Manfreda J, . The use of health-care resources in obesity-hypoventilation syndrome. Chest. 2001;120(2):377–83. [Irrelevant intervention (or time frame)].11502632
83 Berg G, Delaive K, Manfreda J, . The use of health-care resources in obesity-hypoventilation syndrome. Chest. 2001;120(2):377–83. [Irrelevant intervention (or time frame)].11502632
84 Berlowitz DJ, Detering K, Schachter L. A retrospective analysis of sleep quality and survival with domiciliary ventilatory support in motor neuron disease. Amyotrophic Lateral Sclerosise. 2006 Jun;7(2):100–6. PMID: 16753974. [Irrelevant intervention (or time frame)].16753974
85 Berrube L, Declercq PL, Lamia B, . Long-term adherence to domiciliary NIV and its relation to survival in patients with chronic respiratory failure. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841417. [Abstract/conference proceeding].
86 Bertini S, Picariello M, Gorini M, . Telemonitoring in chronic ventilatory failure: a new model of survellaince, a pilot study. Monaldi Archives for Chest Disease. 2012 Jun;77(2):57–66. PMID: 23193842. [Outcomes not reported per device intervention].23193842
87 Bertrand A, Michel FB, Diet J. Treatment of acute respiratory failure by assisted ventilation at home in the Languedoc-Roussillon area. Revue Francaise des Maladies Respiratoires. 1978;6(4):365–72. [Published before 1995].
88 Bhatti H, Ramdass A, Cury JD, . Operator dependent factors implicated in failure of non-invasive positive pressure ventilation (NIPPV) for respiratory failure. The clinical respiratory journal. 2017 Nov;11(6):901–5. PMID: 26663322. [Irrelevant intervention (or time frame)].26663322
89 Biniek R, Humpke T, Topper R. [Home ventilation in neurologic diseases. Survey of 62 patients]. Nervenarzt. 1994 Aug;65(8):536–41. PMID: 7969650. [Published before 1995].7969650
90 Blankenburg T, Roloff D, Schadlich S, . [Hypercapnic failure in patients with COPD under 4 weeks non-invasive, home mechanical ventilation]. Pneumologie. 2008 Mar;62(3):126–31. PMID: 18200455. [Foreign language study].18200455
91 Bleksley JE, Ward NR, Pritchard R, . Review of patient characteristics and their association with survival in patients with COPD on home non-invasive ventilation for hypercapnic respiratory failure: 5 year retrospective study. Thorax. 2017 December;72 (Supplement 3):A149–A50. PMID: 619738725. [Abstract/conference proceeding].
92 Block K, Chevrolet JC, Domenighetti G, . Guidelines for mechanical ventilation at home. [French]. Schweizerische Medizinische Wochenschrift. 1996;126(51-52):2245–50. PMID: 27028828. [Foreign language study].9011937
93 Bockelbrink AG. [Problems with long-term ventilation of neurologic patients]. Medizinische Klinik. 1995 Apr;90(1 Suppl 1):44–6. PMID: 7616921. [Foreign language study].7616921
94 Boehringer I. Multiple Dose Comparison of Tiotropium Inhalation Capsules, Salmeterol Inhalation Aerosol and Placebo in Patients With Chronic Obstructive Pulmonary Disease (COPD). 1999 February. PMID: NCT02172287. [Irrelevant intervention (or time frame)].
95 Bokhari S, Bentley A, Chaudhry N. Demographics of patients with chronic obstructive pulmonary disease (COPD) being referred and set up on home mechanical ventilation (HMV) between 2000 and 2013. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849066. [Abstract/conference proceeding].
96 Bolton CE, Bevan-Smith EF, Blakey JD, . British Thoracic Society guideline on pulmonary rehabilitation in adults: accredited by NICE. Thorax. 2013;68:(Suppl 2):ii1–ii30.[Duplicate Study].23880483
97 Bonnaud F, Lemoigne F, Blaive B. [Compliance with long-term respiratory assistance in patients with chronic respiratory insufficiency]. Revue des Maladies Respiratoires. 1985;2(3):155–9. PMID: 4081282. [Published before 1995].4081282
98 Borel J, Tamisier R, Gonzalez-barmejo J, . One-month of non-invasive ventilation in obesity hypoventilation syndrome improves sleep architecture and blood gazes but has no impact on inflammatory, metabolic and cardiovascular status: A randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2010;181(1 MeetingAbstracts). PMID: 70843023. [Abstract/conference proceeding].
99 Borel J, Tamisier R, Gonzalez-Bermejo J, . Non-invasive ventilation in obesity hypoventilation syndrome: A randomized controlled trial. Journal of Sleep Research. 2010 September;19:19–20. PMID: 70284940. [Abstract/conference proceeding].19895422
100 Borel J-C, Burel B, Tamisier R, . Comorbidities and mortality in hypercapnic obese under domiciliary noninvasive ventilation. PLoS ONE [Electronic Resource]. 2013;8(1):e52006. PMID: 23341888. [Unclear device].23341888
101 Borel JC, Pelletier J, Taleux N, . Parameters recorded by software of non-invasive ventilators predict copd exacerbation: A proof-ofconcept study. Thorax. 2015 01 Mar;70(3):284–5. PMID: 602260362. [Abstract/conference proceeding].25582449
102 Borel J-C, Pepin J-L, Pison C, . Long-term adherence with non-invasive ventilation improves prognosis in obese COPD patients. Respirology. 2014 Aug;19(6):857–65. PMID: 24912564. [Irrelevant intervention (or time frame)].24912564
103 Borel JC, Tamisier R, Gonalezez-Barmejo J, . One-month Of Non-Invasive Ventilation In Obesity Hypoventilation Syndrome Improves Sleep Architecture And Blood Gazes But Has No Impact On Inflammatory, Metabolic And Cardiovascular Status: A Randomized Controlled Trial [Abstract]. American journal of respiratory and critical care medicine. 2010;181(Meeting Abstracts):A5576. PMID: CN-00758903 UPDATE. [Abstract/conference proceeding].
104 Borel JC, Verges S, Pepin JL, . Home exercise training with non-invasive ventilation in thoracic restrictive respiratory disorders: A randomised study. Respiratory Physiology and Neurobiology. 2009 30 Jun;167(2):168–73. PMID: 50519913. [Irrelevant intervention (or time frame)].19442592
105 Borge JH, Del Carmen Garcia Garcia M, Rodriguez MJA, . Outcome of non-invasive domiciliary ventilation in elderly patients. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614777694. [Abstract/conference proceeding].
106 Borghi-Silva A, Di Thommazo L, Pantoni CBF, . Non-invasive ventilation improves peripheral oxygen saturation and reduces fatigability of quadriceps in patients with COPD. Respirology. 2009 May;14(4):537–44. PMID: 19386071. [Irrelevant intervention (or time frame)].19386071
107 Borghi-Silva A, Mendes RG, Toledo AC, . Adjuncts to physical training of patients with severe COPD: oxygen or noninvasive ventilation? Respiratory Care. 2010 Jul;55(7):885–94. PMID: 20587101. [Irrelevant intervention (or time frame)].20587101
108 Borghi-Silva A, Reis MS, Mendes RG, . Noninvasive ventilation acutely modifies heart rate variability in chronic obstructive pulmonary disease patients. Respiratory Medicine. 2008 Aug;102(8):1117–23. PMID: 18585024. [Irrelevant intervention (or time frame)].18585024
109 Bosi M, Crociani L, Fiorentini F. Nocturnal Cardiorespiratory Monitoring and treatment of patient-ventilator asynchrony. [Italian]. Rassegna di Patologia dell’Apparato Respiratorio. 2009 June;24(3):173–80. PMID: 355330149. [Foreign language study].
110 Botel U, Glaser E, Niedeggen A, . The cost of ventilator-dependent spinal cord injuries-patients in the hospital and at home. Spinal Cord. 1997 Jan;35(1):40–2. PMID: 9025219. [Irrelevant study design].9025219
111 Bouloukaki I, Mermigkis C, Protopapadakis C, . Long term effects of compliance with positive airway pressure (PAP) therapy in patients with obesity hypoventilation syndrome (OHS). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780823. [Abstract/conference proceeding].
112 Bourbeau J, Viejo J, Koehler D, . Geographic differences in oxygen therapy prescriptions in the COPD patient management European trial (COMET). American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2015;191(no pagination). PMID: 72053705. [Abstract/conference proceeding].
113 Bourke SC, Steer J. Practical respiratory management in amyotrophic lateral sclerosis: evidence, controversies and recent advances. Neurodegenerative Disease Management. 2016 Apr;6(2):147–60. PMID: 27033240. [Abstract/conference proceeding].27033240
114 Boussaid G, Prigent H, Laforet P, . Effect and impact of mechanical ventilation in myotonic dystrophy type 1: a prospective cohort study. Thorax. 2018 Mar 23;23:23. PMID: 29572271. [Irrelevant comparison or no comparison].29572271
115 Brasil Santos D, Vaugier I, Boussaid G, . Impact of Noninvasive Ventilation on Lung Volumes and Maximum Respiratory Pressures in Duchenne Muscular Dystrophy. Respiratory Care. 2016 Nov;61(11):1530–5. PMID: 27794082. [Irrelevant comparison or no comparison].27794082
116 Braunlich J, Seyfarth HJ, Wirtz H. Nasal High-flow versus non-invasive ventilation in stable hypercapnic COPD: a preliminary report. Multidisciplinary Respiratory Medicine. 2015 01 Dec;10 (1) (no pagination)(19). PMID: 605894077. [Irrelevant comparison or no comparison].
117 Brigham WsH. Sleep Disorders Management, Health and Safety in Police. 2005 May. PMID: NCT00207285. [Irrelevant patient (age, medical condition)].
118 Brito V, Spiegler P. The overlap syndrome-strengthening the argument for CPAP. Clinical Pulmonary Medicine. 2011 September;18(5):250. PMID: 362542890. [Abstract/conference proceeding].
119 Brochard L. Non-invasive ventilation in acute respiratory failure. [French]. Medecine Therapeutique. 2001;7(10):748–53. PMID: 34086975. [Foreign language study].
120 Brooks D, De Rosie J, Mousseau M, . Long term follow-up of ventilated patients with thoracic restrictive or neuromuscular disease. Canadian Respiratory Journal. 2002;9(2):99–106. PMID: 34732668. [Outcomes not reported per device intervention].11972163
121 Brooks D, King A, Tonack M, . User perspectives on issues that influence the quality of daily life of ventilator-assisted individuals with neuromuscular disorders. Canadian Respiratory Journal. 2004 November/December;11(8):547–54. PMID: 40089891. [Irrelevant study design].15611803
122 Brown JP, Bauman KA, Kurili A, . Positive airway pressure therapy for sleep-disordered breathing confers short-term benefits to patients with spinal cord injury despite widely ranging patterns of use. Spinal Cord. 2018 Mar 07;07:07. PMID: 29515212. [Irrelevant comparison or no comparison].29515212
123 Bry C, Jaffre S, Guyomarc’h B, . Noninvasive Ventilation in Obese Subjects After Acute Respiratory Failure. Respiratory Care. 2018 Jan;63(1):28–35. PMID: 28974645. [Irrelevant intervention (or time frame)].28974645
124 Brywczynski JJ, Barrett TW, Schriger DL. Out-of-Hospital Continuous Positive Airway Pressure Ventilation Versus Usual Care in Acute Respiratory Failure: A Randomized Controlled Trial. Answers to the September 2008 Journal Club Questions. Annals of Emergency Medicine. 2009 February;53(2):272–83. PMID: 354077173. [Irrelevant study design].19167622
125 Buchan KAM, Badlan K, Fletcher M, . Does exercising with domiciliary non-invasive ventilation (NIV) improve quality of life (QOL) in patients with severe chronic obstructive pulmonary disease (COPD)? Thorax. 2014 December;69:A66. PMID: 71688781. [Abstract/conference proceeding].
126 Budd R, Smith GA, Rohr V. Noninvasive positive pressure ventilation. Changing the respiratory distress prehospital paradigm of ventilation & intubation. Journal of Emergency Medical Services. 2014 Nov;39(11):22–7. PMID: 25630159. [Irrelevant study design].25630159
127 Budweiser S, Heinemann F, Fischer W, . Impact of ventilation parameters and duration of ventilator use on non-invasive home ventilation in restrictive thoracic disorders. Respiration. 2006;73(4):488–94. PMID: 16205051. [Irrelevant study design].16205051
128 Budweiser S, Heinemann F, Fischer W, . Long-term reduction of hyperinflation in stable COPD by non-invasive nocturnal home ventilation. Respiratory Medicine. 2005 Aug;99(8):976–84. PMID: 15950138. [Irrelevant patient (age, medical condition)].15950138
129 Budweiser S, Hitzl AP, Jorres RA, . Health-related quality of life and long-term prognosis in chronic hypercapnic respiratory failure: a prospective survival analysis. Respiratory Research. 2007 Dec 17;8:92. PMID: 18086309. [Unclear device].18086309
130 Budweiser S, Jorres RA, Pfeifer M. Noninvasive home ventilation for chronic obstructive pulmonary disease: indications, utility and outcome. Current Opinion in Pulmonary Medicine. 2008 Mar;14(2):128–34. PMID: 18303422. [Irrelevant study design].18303422
131 Budweiser S, Jorres RA, Riedl T, . Predictors of survival in COPD patients with chronic hypercapnic respiratory failure receiving noninvasive home ventilation. Chest. 2007 Jun;131(6):1650–8. PMID: 17565016. [Irrelevant outcome].17565016
132 Budweiser S, Murbeth RE, Jorres RA, . Predictors of long-term survival in patients with restrictive thoracic disorders and chronic respiratory failure undergoing non-invasive home ventilation. Respirology. 2007 Jul;12(4):551–9. PMID: 17587422. [Irrelevant study design].17587422
133 Budweiser S, Riedl S, Jörres R, . Mortality and prognostic factors in patients with obesity‐hypoventilation syndrome undergoing noninvasive ventilation. Journal of internal medicine. 2007;261(4):375–83. [Irrelevant comparison or no comparison].17391112
134 Bukumirovic V, Stevic Z, Zugic V, . Our experience in home mechanical ventilation. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71924008. [Abstract/conference proceeding].
135 Bullemer F, Heindl S, Pahnke J, . [Noninvasive intermittent ventilation. A prospective data collection in patients with hypoventilation syndrome]. Medizinische Klinik. 1996 Apr 12;91 Suppl 2:14–6. PMID: 8684316. [Foreign language study].8684316
136 Bullemer F, Kroworsch P, Heindl S, . Exercise tolerance of patients under nasal intermittent positive pressure ventilation (nIPPV). [German]. Medizinische Klinik. 1999 15 Apr;94(SPEC. ISS. 1):29–31. PMID: 29197439. [Foreign language study].29197439
137 Bwika J, Ali A, O’Sullivan O, . Changing trends in domiciliary non-invasive ventilation (NIV) set-up. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841411. [Abstract/conference proceeding].
138 Callegari J, Magnet FS, Taubner S, . Interfaces and ventilator settings for long-term noninvasive ventilation in COPD patients. International Journal of COPD. 2017 28 Jun;12:1883–9. PMID: 617118664. [Irrelevant outcome].28721033
139 Cambridge University Hospitals NHSFT, University of C, King’s College L. Trial of a Breathlessness Intervention Service for Intractable Breathlessness. 2008 August. PMID: NCT00678405. [Irrelevant patient (age, medical condition)].
140 Cano M, Martin C, Zamora E, . Non-invasive home ventilation: Indications are changing. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2010;181(1 MeetingAbstracts). PMID: 70840511. [Abstract/conference proceeding].
141 Cano NJ, Pichard C, Court-Fortune I, . Survival of patients with chronic respiratory failure on long-term oxygen therapy and or non-invasive ventilation at home. Clinical Nutrition. 2015 Aug;34(4):739–44. PMID: 25240804. [Irrelevant intervention (or time frame)].25240804
142 Cano NJM, Roth H, Court-Ortune I, . Nutritional depletion in patients on long-term oxygen therapy and/or home mechanical ventilation. European Respiratory Journal. 2002 Jul;20(1):30–7. PMID: 12166577. [Irrelevant comparison or no comparison].12166577
143 Carlucci A, Pisani L, Ceriana P, . Patient-ventilator asynchronies: may the respiratory mechanics play a role? Critical Care (London, England). 2013 Mar 25;17(2):R54. PMID: 23531269. [Irrelevant intervention (or time frame)].23531269
144 Carratu P, Spicuzza L, Cassano A, . Early treatment with noninvasive positive pressure ventilation prolongs survival in Amyotrophic Lateral Sclerosis patients with nocturnal respiratory insufficiency. Orphanet Journal Of Rare Diseases. 2009 Mar 10;4:10. PMID: 19284546. [Outcomes not reported per device intervention].19284546
145 Carrillo A, Ferrer M, Gonzalez-Diaz G, . Noninvasive ventilation in acute hypercapnic respiratory failure caused by obesity hypoventilation syndrome and chronic obstructive pulmonary disease. American journal of respiratory and critical care medicine. 2012;186(12):1279–85. [Irrelevant setting/location],23103736
146 Carter RE, Donovan WH, Halstead L, . Comparative study of electrophrenic nerve stimulation and mechanical ventilatory support in traumatic spinal cord injury. Paraplegia. 1987 Apr;25(2):86–91. PMID: 3495773. [Published before 1995].3495773
147 Carvalho EV, Holsapfel SGA, Caromano FA, . Profile of patients with amyotrophic lateral sclerosis at the time of non-invasive ventilation. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2017 November;18 (Supplement 2):291–2. PMID: 619350245. [Abstract/conference proceeding].28281365
148 Casas JP, Robles AM, Pereyra MA, . [Domiciliary noninvasive positive pressure ventilation in chronic alveolar hypoventilation]. Medicina. 2000;60(5 Pt 1):545–50. PMID: 11188889. [Foreign language study].11188889
149 Cascon JA, Fernandez R, Rubinos G, . Significant weight loss contribute to the withdrawal of home mechanical ventilation in patients with obesity hypoventilation syndrome. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2014;189(no pagination). PMID: 72043107. [Abstract/conference proceeding].
150 Cazzolli P, Brooks B, Nakayama Y, . The Oral Secretion Scale (OSS) predicts tolerance of non-invasive ventilation (NIV), the need for hospice or transition to tracheostomy ventilation (TV) and prognostic factors for survival in patients with ALS/MND. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2017 November;18 (Supplement 2):52–3. PMID: 619349859. [Abstract/conference proceeding].
151 Cazzolli P, Brooks BR, Lewarski J, . Oral Secretion Scale score in amyotrophic lateral sclerosis patients is associated with tolerance of Noninvasive Positive Pressure Ventilation, need for hospice or transition to Tracheal Positive Pressure Ventilation and survival. Amyotrophic Lateral Sclerosis. 2010 November;11:140. PMID: 70297667. [Abstract/conference proceeding].19551535
152 Cazzolli PA, Oppenheimer EA. Home mechanical ventilation for amyotrophic lateral sclerosis: nasal compared to tracheostomy-intermittent positive pressure ventilation. Journal of the Neurological Sciences. 1996 Aug;139 Suppl:123–8. PMID: 8899671. [Irrelevant comparison or no comparison].8899671
153 Centocor I. A Study of Safety and Efficacy of CNTO 148 in Patients With Severe Persistent Asthma. 2004 August. PMID: NCT00207740. [Irrelevant patient (age, medical condition)].
154 Centre d’Investigation Clinique et T. Concordance Between ETCO2, PTCO2 and PaCO2 in the Home-ventilated Neuromuscular Patient. 2014 April. PMID: NCT02068911. [Completed Clinical Trial].
155 Centre d’Investigation Clinique et T. Long-Term Effect of LIAM on Respiratory Performance in NIV Patients Suffering From Neuromuscular Disease. 2015 October. PMID: NCT02288299. [Irrelevant study design].
156 Centre d’Investigation Clinique et T. Natural History of Cardiac and Respiration Function in Patients With Muscular Dystrophies on Home Mechanical Ventilation. 2016 July. PMID: NCT02501083. [Completed Clinical Trial].
157 Centre Hospitalier Universitaire Saint P. Impact of Telemonitoring to Improve Adherence in Continuous Positive Airway Pressure (CPAP)-Treated Patients. 2016 April. PMID: NCT02773953. [Irrelevant patient (age, medical condition)].
158 Ceriana P, Carlucci A, Piaggi G, . Decannulation and NIV in tracheotomized and chronically ventilated patients. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923950. [Abstract/conference proceeding].
159 Chadda K, Clair B, Orlikowski D, . Pressure support versus assisted controlled noninvasive ventilation in neuromuscular disease. Neurocritical Care. 2004;1(4):429–34. PMID: 41278330. [Irrelevant outcome].16174945
160 Chai HZ, Tan SK, Leow LC, . The effect of acute versus elective initiation of home mechanical ventilation on patient outcome. Respirology. 2016 November;21:127. PMID: 613436444. [Abstract/conference proceeding].
161 Chailleux E, Binet F, Ludot A, . Home treatment for chronic respiratory failure, the ANTADIR experience. [French]. Medecine et Hygiene. 1995;53(2067):825–32. PMID: 25120673. [Foreign language study].25120673
162 Chailleux E, Fauroux B, Binet F, . Predictors of survival in patients receiving domiciliary oxygen therapy or mechanical ventilation: A 10-year analysis of ANTADIR observatory. Chest. 1996;109(3):741–9. PMID: 26086943. [Irrelevant intervention (or time frame)].8617085
163 Chakrabarti B, Young CA, Ando H, . Traditional ventilation monitoring may underestimate the ventilator requirements of motor neurone disease patients. Amyotrophic Lateral Sclerosis. 2011 November;12:54. PMID: 70595717. [Abstract/conference proceeding].
164 Chan K-Y, Cheng LSL, Mak IWC, . Delirium is a Strong Predictor of Mortality in Patients Receiving Non-invasive Positive Pressure Ventilation. Lung. 2017 02;195(1):115–25. PMID: 27787611. [Irrelevant comparison or no comparison].27787611
165 Chang AY, Marsh S, Smith N, . Long-term community non-invasive ventilation. Internal Medicine Journal. 2010 Nov;40(11):764–71. PMID: 20059598. [Irrelevant patient (age, medical condition)].20059598
166 Chang Gung Memorial H. Respiratory Muscle Exercise Training in COPD Patients. 2012 December. PMID: NCT01747694. [Irrelevant intervention (or time frame)].
167 Chang Gung Memorial H. The Impacts of Pulmonary Rehabilitation Therapy on Patients After Thoracic Surgery. 2016 April. PMID: NCT02757092. [Irrelevant patient (age, medical condition)].
168 Channon K, Reilly CC, Parkinson H, . Exploring the benefits of physiotherapy home visits in cystic fibrosis. Journal of Cystic Fibrosis. 2016 June;15:S90. PMID: 614323729. [Abstract/conference proceeding].
169 Chatwin M, Heather S, Hanak A, . Analysis of home support and ventilator malfunction in 1,211 ventilator-dependent patients. European Respiratory Journal. 2010 February;35(2):310–6. PMID: 358253722. [Irrelevant comparison or no comparison].19643945
170 Chatwin M, Nickol AH, Morrell MJ, . Randomised trial of inpatient versus outpatient initiation of home mechanical ventilation in patients with nocturnal hypoventilation. Respiratory Medicine. 2008 Nov;102(11):1528–35. PMID: 18774702. [Unclear device].18774702
171 Chatwin M, Toussaint M, Goncalves MR, . Airway clearance techniques in neuromuscular disorders: A state of the art review. Respiratory Medicine. 2018 Mar;136:98–110. PMID: 29501255. [Irrelevant study design].29501255
172 Chatwin M, Ward S, Nickol AH, . A randomised trial of outpatient versus inpatient initiation of non-invasive ventilation in nocturnal hypoventilation due to neuromuscular and chest wall disease[Abstract]. Thorax. 2004 no: S93, 2004;59(Suppl II):ii–30. PMID: CN-00517392 UPDATE. [Abstract/conference proceeding].
173 Chawla R, Chaudhry D, Kansal S, . Guidelines for noninvasive ventilation in acute respiratory failure. Indian Journal of Critical Care Medicine. 2013 March;17(SUPPL.1):42–70. PMID: 370008855. [Irrelevant patient (age, medical condition)].
174 Cheng L, Chan V, Chu CM. A pilot study of treatment compliance in home noninvasive ventilation. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2011;38(no pagination). PMID: 72117306. [Abstract/conference proceeding].
175 Cheng SL, Chan VL, Chu CM. Compliance with home non-invasive ventilation. Respirology. 2012 May;17(4):735–6. PMID: 364647949. [Abstract/conference proceeding].22420583
176 Chenoweth CE, Washer LL, Obeyesekera K, . Ventilator-associated pneumonia in the home care setting. Infection Control & Hospital Epidemiology. 2007 Aug;28(8):910–5. PMID: 17620236. [Irrelevant patient (age, medical condition)].17620236
177 Cherniack RM, Svanhill E. Long-term use of intermittent positive-pressure breathing (IPPB) in chronic obstructive pulmonary disease. American Review of Respiratory Disease. 1976 Jun;113(6):721–8. PMID: 779547. [Published before 1995].779547
178 Cherniack RM. Intermittent positive pressure breathing in management of chronic obstructive pulmonary disease: current state of the art. American Review of Respiratory Disease. 1974 Dec;110(6 Pt 2):188–92. PMID: 4216280. [Published before 1995].4216280
179 Cheung AP, Chan VL, Liong JT, . A randomised controlled trial of continuation of home non-invasive ventilation vs sham ventilation in survivors of acute hypercapnic respiratory failure in chronic obstructive airway disease [Abstract]. Respirology (Carlton, Vic.). 2008;13:(Suppl 5):A120 [012-04]. PMID: CN-00718321 UPDATE. [Abstract/conference proceeding].
180 Cheung Y, O W, Chan J, . Home ventilation program in patients with chronic respiratory failure due to motor neurone disease. Respirology. 2011 November;16:9. PMID: 70575752. [Abstract/conference proceeding].
181 Chiang LL, Chen SJ, Tsai YH, . [Long-term mechanical ventilation survey]. Changgeng Yi Xue Za Zhi. 1993 Jun;16(2):99–104. PMID: 8339161. [Published before 1995].8339161
182 Chiang L-L, Yu C-T, Liu C-Y, . Six-month nocturnal nasal positive pressure ventilation improves respiratory muscle capacity and exercise endurance in patients with chronic hypercapnic respiratory failure. Journal of the Formosan Medical Association. 2006 Jun;105(6):459–67. PMID: 16801033. [Irrelevant patient (age, medical condition)].16801033
183 Chiusolo F, Fanelli V, Ciofi Degli Atti ML, . CPAP by helmet for treatment of acute respiratory failure after pediatric liver transplantation. Pediatric Transplantation. 2018 02;22(1):02. PMID: 29171131. [Irrelevant patient (age, medical condition)].29171131
184 Cho YB, Kim KB, Lee HJ, . The effect of nasal BiPAP ventilation in acute exacerbation of chronic obstructive airway disease. [Korean]. Tuberculosis and Respiratory Diseases. 1996;43(2):190–200. PMID: 26267496. [Foreign language study].26267496
185 Chu CM, Cheung A, Chan V, . A randomised trial of home non-invasive ventilation vs sham ventilation in survivors of acute hypercapnic respiratory failure in COPD [Abstract]. European Respiratory Society Annual Congress, Berlin, Germany, October. 2008. PMID: CN-00689174 UPDATE. [Abstract/conference proceeding].
186 Chu CM, Cheung AP, Chan VL, . A randomized trial of home non-invasive ventilation vs sham ventilation in survivors of acute hypercapnic respiratory failure in COPD [Abstract]. American Thoracic Society International Conference, May. 2008. PMID: CN-00677033 UPDATE. [Abstract/conference proceeding].
187 Chu CM, Yu WC, Tam CM, . Home mechanical ventilation in Hong Kong. European Respiratory Journal. 2004 Jan;23(1):136–41. PMID: 14738245. [Irrelevant intervention (or time frame)].14738245
188 Chua J, Cahill T, Langan D, . Domicilary non-invasive ventilation in galway-roscommon over 10 years. Irish Journal of Medical Science. 2013 November;182:S474. PMID: 71461985. [Abstract/conference proceeding].
189 Chum M, Gofton T, Shoesmith C. Practice pattern of noninvasive ventilation and its impact on end-of-life care in patients with amyotrophic lateral sclerosis among Canadian care providers. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2016;17:317. PMID: 613441158. [Irrelevant study design].
190 Claman DM, Piper A, Sanders MH, . Nocturnal noninvasive positive pressure ventilatory assistance. Chest. 1996;110(6):1581–8. PMID: 26425164. [Irrelevant study design].8989081
191 Clarke A, Beadle L. Does the provision of home nasal ventilation reduce re-admission rates for patients who were in acute respiratory failure? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71842093. [Abstract/conference proceeding].
192 Clarke BT. Home care in respiratory therapy. Canadian Journal of Respiratory Therapy. 2016;52(2):51–2. PMID: 613687375. [Irrelevant study design].27471424
193 Cleary S R-EJ. Current Trends in Respiratory Care for Individuals with Amyotrophic Lateral Sclerosis. Perspectives in Swallowing and Swallowing Disorders. 2013;22:17–25. [Irrelevant study design].
194 Cleary S, Richman-Eisenstat J. Current Trends in Respiratory Care for Individuals with Amyotrophic Lateral Sclerosis. SIG 13 Perspectives on Swallowing and Swallowing Disorders (Dysphagia). 2013;22(1):17–25. [Irrelevant study design].
195 Cleary S, Wheeler, S., Kalra, S., Kedall, S. & Johnston, W. The effects of manual insufflation therapy on the speech and voice of patients with ALS. Amyotrophic Lateral Sclerosis. 2008;9(1):143. [Irrelevant intervention (or time frame)].
196 Clini EM, Magni G, Crisafulli E, . Home non-invasive mechanical ventilation and long-term oxygen therapy in stable hypercapnic chronic obstructive pulmonary disease patients: comparison of costs. Respiration. 2009;77(1):44–50. PMID: 18417954. [Irrelevant study design].18417954
197 Coelho R, Silva M, Peixoto A, . Percutaneous endoscopic gastrostomy in patients with amyotrophic lateral sclerosis: A case series. United European Gastroenterology Journal. 2015 October;1):A508. PMID: 72267247. [Abstract/conference proceeding].
198 Collard P, Rodenstein DO. Home mechanical ventilation and/or long-term oxygen therapy in chronic obstructive pulmonary disease. Monaldi Archives for Chest Disease. 1993;48(5):441–4. PMID: 24039897. [Published before 1995].8312898
199 Columbia U. Efficacy of Noninvasive Ventilation in Amyotrophic Lateral Sclerosis (ALS). 2007 May. PMID: NCT00537641. [Completed Clinical Trial].
200 Comer DM, Oakes A, Mukherjee R. Domiciliary non-invasive ventilation in the elderly. Effective, tolerated and justified. Ulster Medical Journal. 2015 Jan;84(1):22–5. PMID: 25964699. [Unclear device].25964699
201 Conde B, M.D R. TELE-monitoring in Chronic Obstructive Pulmonary Disease. 2017 June 1. PMID: NCT03129477. [Irrelevant setting/location].
202 Contal O, Adler D, Borel J-C, . Impact of different backup respiratory rates on the efficacy of noninvasive positive pressure ventilation in obesity hypoventilation syndrome: a randomized trial. Chest. 2013 Jan;143(1):37–46. PMID: 22556317. [Irrelevant study design].22556317
203 Contal O, Borel JC, Adler D, . Impact of three back-up rate (BUR) on subjective quality of sleep (QoS) and residual events in obesityhypoventilation (OHS) treated by home non invasive ventilation (NIV): A randomised controlled trial. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2011;38(no pagination). PMID: 72116717. [Abstract/conference proceeding].
204 Coquart JB, Le Rouzic O, Racil G, . Real-life feasibility and effectiveness of home-based pulmonary rehabilitation in chronic obstructive pulmonary disease requiring medical equipment. International Journal of COPD. 2017 12 Dec;12:3549–56. PMID: 619951135. [Irrelevant intervention (or time frame)].29263659
205 Corner E, Garrod R. Does the addition of non-invasive ventilation during pulmonary rehabilitation in patients with chronic obstructive pulmonary disease augment patient outcome in exercise tolerance? A literature review. Physiotherapy Research International. 2010 Mar;15(1):5–15. PMID: 20033880. [Irrelevant setting/location].20033880
206 Costa R, Navalesi P, Spinazzola G, . Comparative evaluation of different helmets on patient-ventilator interaction during noninvasive ventilation. Intensive Care Medicine. 2008 Jun;34(6):1102–8. PMID: 18320168. [Irrelevant study design].18320168
207 Coughlin S, Liang WE, Parthasarathy S. Retrospective Assessment of Home Ventilation to Reduce Rehospitalization in Chronic Obstructive Pulmonary Disease. Journal of Clinical Sleep Medicine. 2015 Jun 15;11(6):663–70. PMID: 25766720. [Irrelevant study design].25766720
208 Coughlin S, Peyerl FW, Munson SH, . Budget impact analysis of home advanced non-invasive ventilation for severe chronic obstructive pulmonary disease. Value in Health. 2016 May;19 (3):A299. PMID: 72312330. [Abstract/conference proceeding].
209 Coughlin S, Peyerl FW, Munson SH, . Cost Savings from Reduced Hospitalizations with Use of Home Noninvasive Ventilation for COPD. Value in Health. 2017 Mar;20(3):379–87. PMID: 28292482. [Irrelevant study design].28292482
210 Coughlin SR, Mawdsley L, Mugarza JA, . Cardiovascular and metabolic effects of CPAP in obese males with OSA. European Respiratory Journal. 2007 Apr;29(4):720–7. PMID: 17251237. [Irrelevant patient (age, medical condition)].17251237
211 Cowie MR, Woehrle H, Wegscheider K, . Adaptive Servo-Ventilation for Central Sleep Apnea in Systolic Heart Failure. N Engl J Med. 2015 Sep 17;373(12):1095–105. doi: 10.1056/NEJMoa1506459. Epub 2015 Sep 1. PMID: 26323938. [Irrelevant patient (age, medical condition)].26323938
212 Cowie MR, Woehrle H, Wegscheider K, . Adaptive servo-ventilation for central sleep apnea in systolic heart failure. New England Journal of Medicine. 2015;373(12):1095–105. [Irrelevant patient (age, medical condition)].26323938
213 Craig H, Education USDo. Follow up Study of Diaphragm Pacing for Patients With High Tetraplegia. 2013 January. PMID: NCT01815554. [Irrelevant patient (age, medical condition)].
214 Crescimanno G, Canino M, Marrone O. Asynchronies and sleep disruption in neuromuscular patients under home noninvasive ventilation. Respiratory Medicine. 2012 Oct;106(10):1478–85. PMID: 22749755. [Irrelevant comparison or no comparison].22749755
215 Crescimanno G, Greco F, Arrisicato S, . Effects of positive end expiratory pressure administration during non‐invasive ventilation in patients affected by amyotrophic lateral sclerosis: A randomized crossover study. Respirology. 2016;21(7):1307–13. [Irrelevant intervention (or time frame)].27323697
216 Crescimanno G, Greco F, Marrone O. Monitoring noninvasive ventilation in neuromuscular patients: Feasibility of unattended home polysomnography and reliability of sleep diaries. Sleep Medicine. 2014 March;15(3):336–41. PMID: 52996794. [Irrelevant patient (age, medical condition)].24513436
217 Crimi C, Noto A, Princi P, . Domiciliary Non-invasive Ventilation in COPD: An International Survey of Indications and Practices. Copd: Journal of Chronic Obstructive Pulmonary Disease. 2016 Aug;13(4):483–90. PMID: 26744042. [Irrelevant study design].26744042
218 Criner G, Gu Q, Murphy P, . CostEffectiveness of Home Oxygen Therapy-Home Mechanical Ventilation (HOT-HMV) for Treatment of Chronic Obstructive Pulmonary Disease (COPD) with Chronic Hypercapnic Respiratory Failure Following an Acute Exacerbation of COPD in the United States (US). A102. DETERMINANTS OF OUTCOMES AND HIGH-VALUE CARE IN COPD. American Thoracic Society; 2018:A2518-A. [Abstract/conference proceeding].
219 Criner GJ, Dreher M, Hart N, . COPD Home Oxygen Therapy and Home Mechanical Ventilation: Improving Admission-Free Survival in Persistent Hypercapnic COPD. Chest. 2018 Jun;153(6):1499–500. PMID: 29884255. [Irrelevant study design].29884255
220 Curtis JK, Liska AP, Rasmussen HK, . IPPB Therapy in Chronic Obstructive Pulmonary Disease: An Evaluation of Long-Term Home Treatment. JAMA: The Journal of the American Medical Association. 1968;206(5):1037–40. [Published before 1995].
221 Cuvelier A, Grigoriu B, Molano LC, . Limitations of transcutaneous carbon dioxide measurements for assessing long-term mechanical ventilation. Chest. 2005 May;127(5):1744–8. PMID: 15888854. [Irrelevant patient (age, medical condition)].15888854
222 Cuvelier A, Molano LC, Muir JF. [Domiciliary ventilation in patients with COPD]. Revue des Maladies Respiratoires. 2005 Sep;22(4):615–33. PMID: 16294181. [Foreign language study].16294181
223 Cuvelier A, Muir JF. Noninvasive ventilation and obstructive lung diseases. European Respiratory Journal. 2001 Jun;17(6):1271–81. PMID: 11491176. [Irrelevant study design].11491176
224 Dale L, Brocklebank D. An outcome evaluation of a local respiratory support service. Journal of Sleep Research. 2012 September;21:347. PMID: 70928069. [Abstract/conference proceeding].
225 Deasy KF, Ibrahim H, Ronan NJ, . Non-invasive ventilation in the management of motor neurone disease. An examination of compliance. Irish Journal of Medical Science. 2017 October;186 (Supplement 10):S437. PMID: 619504142. [Abstract/conference proceeding].
226 Del Carmen Garcia Garcia M, Borge JH, Goncalves PP, . Home mechanical ventilation in the elderly. Chest. Conference: CHEST World Congress. 2014;145(3 MEETING ABSTRACT). PMID: 71429111. [Abstract/conference proceeding].
227 Delanoye JJ, Bouduin S, Derom E, . Adherence to home mechanical ventilation (HMV). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105160. [Abstract/conference proceeding].
228 Dellborg C, Olofson J, Midgren B, . Impact of home mechanical ventilation on health-related quality of life in patients with chronic alveolar hypoventilation: a prospective study. The clinical respiratory journal. 2008 Jan;2(1):26–35. PMID: 20298301. [Irrelevant patient (age, medical condition)].20298301
229 Deng T, Wang Y, Sun M, . Stage-matched intervention for adherence to CPAP in patients with obstructive sleep apnea: a randomized controlled trial. Sleep & Breathing. 2013 May;17(2):791–801. PMID: 22945541. [Irrelevant patient (age, medical condition)].22945541
230 Diaz O, Begin P, Andresen M, . Physiological and clinical effects of diurnal noninvasive ventilation in hypercapnic COPD. European Respiratory Journal. 2005 Dec;26(6):1016–23. PMID: 16319330. [Irrelevant intervention (or time frame)].16319330
231 Discussion: Noninvasive ventilation for acute respiratory failure. Respiratory Care. 2013 01 Jun;58(6):970–2. PMID: 369024651. [Irrelevant study design].
232 Divo MJ, Murray S, Cortopassi F, . Prolonged mechanical ventilation in Massachusetts: the 2006 prevalence survey. Respiratory Care. 2010 Dec;55(12):1693–8. PMID: 21122178. [Irrelevant outcome].21122178
233 Doddamreddy P, Singh G, Schultz B, . Factors influencing noninvasive ventilation initiation in amyotrophic lateral sclerosis. Chest. 2017 October;152 (4 Supplement 1):A187. PMID: 619297444. [Abstract/conference proceeding].
234 Dogan OT, Turkyilmaz S, Berk S, . Effects of long-term non-invasive home mechanical ventilation on chronic respiratory failure. Current Medical Research & Opinion. 2010 Sep;26(9):2229–36. PMID: 20690890. [Outcomes not reported per device intervention].20690890
235 Doherty LS, McNicholas WT. Home mechanical ventilation. Irish Medical Journal. 2005 July/August;98(7):202–6. PMID: 41288402. [Irrelevant study design].16185015
236 Domenech-Clar R, Nauffal-Manssur D, Compte-Torrero L, . Adaptation and follow-up to noninvasive home mechanical ventilation: ambulatory versus hospital. Respiratory Medicine. 2008 Nov;102(11):1521–7. PMID: 18775656. [Unclear device].18775656
237 Domicile IPS. Initiation of Non-Invasive Ventilation at Home Versus Hospital Among Patients With Overlap Syndrome. 2015 February. PMID: NCT02363413. [Completed Clinical Trial].
238 Donner CF, Howard P, Robert D. Patient selection and techniques for home mechanical ventilation. European Respiratory Society Rehabilitation and Chronic Care Scientific Group. Monaldi Archives for Chest Disease. 1993;48(1):40–7. PMID: 8472063. [Published before 1995].8472063
239 Donvito G, Lupone S, De Mattia E, . A new tool to improve oral communication during non-invasive ventilation in amyotrophic lateral sclerosis patients. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2017 November;18 (Supplement 2):314–5. PMID: 619350167. [Abstract/conference proceeding].
240 Drake S, Ramsay M, Steier J, . Change in patient demographics and Home Mechanical Ventilation (HMV) set up for patients with chronic respiratory failure between 2006 and 2012. Thorax. 2013 December;68:A46. PMID: 71367109. [Abstract/conference proceeding].
241 Dreher M, Doncheva E, Schwoerer A, . Preserving oxygenation during walking in severe chronic obstructive pulmonary disease: noninvasive ventilation versus oxygen therapy. Respiration. 2009;78(2):154–60. PMID: 19092234. [Irrelevant intervention (or time frame)].19092234
242 Dreher M, Rauter I, Storre JH, . When should home mechanical ventilation be started in patients with different neuromuscular disorders? Respirology. 2007 Sep;12(5):749–53. PMID: 17875066. [Irrelevant outcome].17875066
243 Dreher M, Windisch W. Home mechanical ventilation: Indications and outcome. [German]. Pneumologe. 2010 March;7(2):114–20. PMID: 50782644. [Foreign language study].
244 Dretzke J, Blissett D, Dave C, . The cost-effectiveness of domiciliary non-invasive ventilation in patients with end-stage chronic obstructive pulmonary disease: a systematic review and economic evaluation. Health Technology Assessment (Winchester, England). 2015 Oct;19(81):1–246. PMID: 26470875. [Irrelevant study design].26470875
245 Dretzke J, Dave C, Blissett D, . The clinical effectiveness of domiciliary non-invasive ventilation (NIV) in patients with end-stage COPD. Thorax. 2014 December;69:A205–A6. PMID: 71689064. [Abstract/conference proceeding].
246 Dreyer P, Lorenzen CK, Schou L, . Survival in ALS with home mechanical ventilation non-invasively and invasively: a 15-year cohort study in west Denmark. Amyotrophic Lateral sclerosis & Frontotemporal Degeneration. 2014 Mar;15(1-2):62–7. PMID: 24067168. [Unclear device].24067168
247 Dreyer P. Living and dying with invasive home mechanical ventilation in patients with advanced ALS: Decision-making, survival and withdrawal. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2015;16:27. PMID: 72104320. [Abstract/conference proceeding].
248 Dreyer PS, Felding M, Klitnaes CS, . Withdrawal of invasive home mechanical ventilation in patients with advanced amyotrophic lateral sclerosis: ten years of Danish experience. Journal of Palliative Medicine. 2012 Feb;15(2):205–9. PMID: 22283411. [Irrelevant comparison or no comparison].22283411
249 Dudeffant P, Manier G, Gbikpi-Benissan G, . [Outcome of patients with chronic respiratory insufficiency treated at home with tracheotomy and assisted ventilation]. Revue des Maladies Respiratoires. 1985;2(3):145–50. PMID: 4081280. [Published before 1995].4081280
250 Duiverman ML, Bladder G, Meinesz AF, . Home mechanical ventilatory support in patients with restrictive ventilatory disorders: a 48-year experience. Respiratory Medicine. 2006 Jan;100(1):56–65. PMID: 15939581. [Irrelevant intervention (or time frame)].15939581
251 Duiverman ML, Huberts AS, van Eykern LA, . Respiratory muscle activity and patient-ventilator asynchrony during different settings of noninvasive ventilation in stable hypercapnic COPD: does high inspiratory pressure lead to respiratory muscle unloading? International Journal of Copd. 2017;12:243–57. PMID: 28138234. [Irrelevant intervention (or time frame)].28138234
252 Duiverman ML, Maagh P, Magnet F, . Impact of high-intensity non-invasive ventilation on cardiac function in stable hypercapnic COPD: A randomised cross-over trial. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614779964. [Abstract/conference proceeding].
253 Duiverman ML, Windisch W, Storre JH, . The role of NIV in chronic hypercapnic COPD following an acute exacerbation: the importance of patient selection? Therapeutic Advances in Respiratory Disease. 2016 Apr;10(2):149–57. PMID: 26746384. [Irrelevant study design].26746384
254 Durocher AM, Thevenon A, Grattepanche E, . Breathing assistance at home in the elderly. [French]. Annales de Readaptation et de Medecine Physique. 1988;31(1):69–75. PMID: 18059885. [Published before 1995].18059885
255 Dwarakanath A, Elliott MW. Noninvasive ventilation in the management of acute hypercapnic respiratory failure. Breathe. 2013 01 Sep;10(1):339–48. PMID: 369794935. [Irrelevant study design].
256 Dybwik K, Nielsen EW, Brinchmann BS. Ethical challenges in home mechanical ventilation: a secondary analysis. Nursing Ethics. 2012 Mar;19(2):233–44. PMID: 22183963. [Irrelevant study design].22183963
257 Dyrstad DN, Hansen BS, Gundersen EM. Factors that influence user satisfaction: tracheotomised home mechanical ventilation users’ experiences. Journal of Clinical Nursing. 2013 Feb;22(3-4):331–8. PMID: 23240989. [Irrelevant patient (age, medical condition)].23240989
258 e Lucas-Ramos P, e Miguel-Diez J, Santacruz-Siminiani A, . Benefits at 1 year of nocturnal intermittent positive pressure ventilation in patients with obesity-hypoventilation syndrome. Respiratory Medicine. 2004 October;98(10):961–7. PMID: 40029127. [Irrelevant study design].15481272
259 Eagle M, Bourke J, Bullock R, . Managing Duchenne muscular dystrophy-the additive effect of spinal surgery and home nocturnal ventilation in improving survival. Neuromuscular Disorders. 2007 Jun;17(6):470–5. PMID: 17490881. [Irrelevant patient (age, medical condition)].17490881
260 Economou NT, Ilias I, Velentza L, . Sleepiness, fatigue, anxiety and depression in chronic obstructive pulmonary disease and obstructive sleep apnea - overlap - syndrome, before and after continuous positive airways pressure therapy. PLoS ONE. 2018 June;13 (6) (no pagination)(e0197342). PMID: 622516724. [Irrelevant patient (age, medical condition)].29889828
261 Efficacy and Safety Study of Benralizumab in Patients With Uncontrolled Asthma on Medium to High Dose Inhaled Corticosteroid Plus LABA (MIRACLE). 2017 September 15. PMID: NCT03186209. [Irrelevant patient (age, medical condition)].
262 Ekkernkamp E, Storre JH, Windisch W, . Impact of intelligent volume-assured pressure support on sleep quality in stable hypercapnic chronic obstructive pulmonary disease patients: a randomized, crossover study. Respiration; international review of thoracic diseases. 2014;88(4):270–6. PMID: CN-00999996 UPDATE. [Irrelevant study design].25171686
263 Ekkernkamp E, Walker D, Storre JH, . Sleep quality during different noninvasive ventilation strategies in stable hypercapnic chronic obstructive pulmonary disease. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2012;185(no pagination). PMID: 71987714. [Abstract/conference proceeding].
264 Eller J, Priesnitz M, Lode H. Results of domiciliary treatment with IPPB in COLD patients. [German]. Atemwegs- und Lungenkrankheiten. 1989;15(8):340–1. PMID: 19222897. [Published before 1995].19222897
265 Elliott MW, Simonds AK, Carroll MP, . Domiciliary nocturnal nasal intermittent positive pressure ventilation in hypercapnic respiratory failure due to chronic obstructive lung disease: effects on sleep and quality of life. Thorax. 1992 May;47(5):342–8. PMID: 1609376. [Published before 1995].1609376
266 Ellis ER, Grunstein RR, Chan S, . Noninvasive ventilatory support during sleep improves respiratory failure in kyphoscoliosis. Chest. 1988 Oct;94(4):811–5. PMID: 3139373. [Published before 1995].3139373
267 Elsa C, Charlotte G, Frederic V, . Non-invasive ventilation in acute hypoxemic respiratory failure. Annals of Intensive Care. Conference: French Intensive Care Society, International Congress Reanimation. 2018;8(1 Supplement 1). PMID: 620836995. [Abstract/conference proceeding].
268 El-Solh AA, Aquilina A, Pineda L, . Noninvasive ventilation for prevention of post-extubation respiratory failure in obese patients. European Respiratory Journal. 2006 Sep;28(3):588–95. PMID: 16737982. [Irrelevant setting/location].16737982
269 Embid C, Dalmases M, Nunez M, . Non-invasive ventilation at home (NIV): Characteristics at the beginning and relationship with 10-years survival. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2012;185(no pagination). PMID: 71987703. [Abstract/conference proceeding].
270 Eng D. Management guidelines for motor neurone disease patients on non-invasive ventilation at home. Palliative Medicine. 2006 Mar;20(2):69–79. PMID: 16613402. [Irrelevant study design].16613402
271 Escarrabill J, Tebe C, Espallargues M, . Variability in home mechanical ventilation prescription. Archivos de Bronconeumologia. 2015 Oct;51(10):490–5. PMID: 25618455. [Irrelevant comparison or no comparison].25618455
272 Escarrabill J, Vianello A, Farrero E, . Place of death in patients with amyotrophic lateral sclerosis. Revista Portuguesa de Pneumologia. 2014 Jul-Aug;20(4):188–93. PMID: 24785570. [Irrelevant outcome].24785570
273 Estopa Miro R, Villasante Fernandez-Montes C, e Lucas Ramos P, . [Guidelines for domiciliary mechanical ventilation. Working Group on Home Mechanical Ventilation]. Archivos de Bronconeumologia. 2001 Mar;37(3):142–9. PMID: 11333540. [Foreign language study].11333540
274 Eun L, Kang SW, Choi JY. Cardiac function associated with home ventilator care in duchenne muscular dystrophy. Cardiology in the Young. 2017 July;27 (4):S321–S2. PMID: 620077128. [Abstract/conference proceeding].
275 Fanfulla F, Delmastro M, Berardinelli A, . Effects of different ventilator settings on sleep and inspiratory effort in patients with neuromuscular disease. American Journal of Respiratory and Critical Care Medicine. 2005 01 Sep;172(5):619–24. PMID: 41232974. [Irrelevant setting/location].15961699
276 Fanfulla F, Taurino AE, Lupo ND, . Effect of sleep on patient/ventilator asynchrony in patients undergoing chronic non-invasive mechanical ventilation. Respiratory Medicine. 2007 August;101(8):1702–7. PMID: 46930711. [Irrelevant outcome].17448652
277 Farre R, Navajas D, Prats E, . Performance of mechanical ventilators at the patient’s home: a multicentre quality control study. Thorax. 2006 May;61(5):400–4. PMID: 16467068. [Irrelevant study design].16467068
278 Farrero E, Prats E, Manresa F, . Outcome of non-invasive domiciliary ventilation in elderly patients. Respiratory Medicine. 2007 Jun;101(6):1068–73. PMID: 17126543. [Outcomes not reported per device intervention].17126543
279 Fauroux B, Howard P, Muir JF. Home treatment for chronic respiratory insufficiency: the situation in Europe in 1992. The European Working Group on Home Treatment for Chronic Respiratory Insufficiency. European Respiratory Journal. 1994 Sep;7(9):1721–6. PMID: 7995407. [Published before 1995].7995407
280 Fauroux B, Le Roux E, Ravilly S, . Long-term noninvasive ventilation in patients with cystic fibrosis. Respiration. 2008;76(2):168–74. PMID: 17989500. [Irrelevant outcome].17989500
281 Fayssoil A, Ben Yaou R, Ogna A, . Left bundle branch block in Duchenne muscular dystrophy: Prevalence, genetic relationship and prognosis. Archives of Cardiovascular Diseases Supplements. 2018 January;10 (1):34–5. PMID: 620309258. [Abstract/conference proceeding].
282 Felding M, Dreyer P. Withdrawal of invasive home mechanical ventilation in advance stage ALS patients. Amyotrophic Lateral Sclerosis. 2009;10:190. PMID: 70078652. [Abstract/conference proceeding].
283 Fernandez Alvarez R, Rabec C, Rubinos Cuadrado G, . Monitoring Noninvasive Ventilation in Patients with Obesity Hypoventilation Syndrome: Comparison between Ventilator Built-in Software and Respiratory Polygraphy. Respiration. 2017;93(3):162–9. PMID: 28088804. [Irrelevant intervention (or time frame)].28088804
284 Fernandez Alvarez R, Rubinos Cuadrado G, Rodriguez Jerez F, . Home mechanical ventilation through mask: monitoring leakage and nocturnal oxygenation at home. Respiration. 2013;85(2):132–6. PMID: 23018542. [Irrelevant outcome].23018542
285 Fernandez R, Cabrera C, Rubinos G, . Nasal versus oronasal mask in home mechanical ventilation: the preference of patients as a strategy for choosing the interface. Respiratory Care. 2012 Sep;57(9):1413–7. PMID: 22348645. [Irrelevant outcome].22348645
286 Fernandez-Alvarez R, Rubinos-Cuadrado G, Cabrera-Lacalzada C, . [Home mechanical ventilation: dependency and burden of care in the home]. Archivos de Bronconeumologia. 2009 Aug;45(8):383–6. PMID: 19523734. [Foreign language study].19523734
287 Ferrer M, Esquinas A, Leaon M, . Noninvasive ventilation (NIV) in severe hypoxemic acute respiratory failure (ARF). A randomized clinical trial. European respiratory journal. 2001;18:(Suppl 33):185s. PMID: CN-00393467 UPDATE. [Irrelevant setting/location].
288 Fiksa J, Vymětalová P, Stach Z, . Evaluation of ventilation parameters in neurological patients. Ceska a Slovenska Neurologie a Neurochirurgie. 2003;66(4):251–7. [Abstract/conference proceeding].
289 Fiorentino G, Esquinas AM. Initiation of Non-invasive ventilation in amyotrophic lateral sclerosis: looking for some details from the guidelines. Amyotrophic Lateral sclerosis & Frontotemporal Degeneration. 2017 May;18(3-4):307–8. PMID: 28288524. [Irrelevant study design].28288524
290 Fiorenza D, Vitacca M, Clini E. Hospital monitoring, setting and training for home non invasive ventilation. Monaldi Archives for Chest Disease. 2003 Apr-Jun;59(2):119–22. PMID: 14635499. [Irrelevant study design].14635499
291 Fisher PH. CPAP In-home Assessment Australia. 2016 July. PMID: NCT02809794. [Irrelevant patient (age, medical condition)].
292 Fisher PH. CPAP In-home Assessment NZ. 2016 July. PMID: NCT02804919. [Irrelevant patient (age, medical condition)].
293 Fisk WJ. How home ventilation rates affect health: A literature review. Indoor Air. 2018 Jul;28(4):473–87. PMID: 29705988. [Irrelevant study design].29705988
294 Fletcher SV, Ewles S, Wilkinson JE. The changing face of home NIV (Non invasive ventilation). Thorax. 2012 December;67:A163–A4. PMID: 71126403. [Abstract/conference proceeding].
295 Fondazione Don Carlo Gnocchi O, Fondazione Salvatore M. “New Perspectives of Adaptation to NIV in ALS”. 2015 January. PMID: NCT02537132. [Completed Clinical Trial].
296 Fondazione Salvatore M. Feasibility Study of a Home Rehabilitative Network to Treat Prolonged Weaned Patients. 2011 July. PMID: NCT01577927. [Irrelevant patient (age, medical condition)].
297 Fox GA. A brief update: Current activities at the Canadian Thoracic Society. Canadian Respiratory Journal. 2011 November-December;18(6):311–2. PMID: 364710958. [Abstract/conference proceeding].
298 Frat J-P, Ricard J-D, Coudroy R, . Preoxygenation with non-invasive ventilation versus high-flow nasal cannula oxygen therapy for intubation of patients with acute hypoxaemic respiratory failure in ICU: the prospective randomised controlled FLORALI-2 study protocol. BMJ Open. 2017 12 22;7(12):e018611. PMID: 29275345. [Irrelevant study design].29275345
299 Frederiksberg University H, Foundation T, The TF, . The Virtual Hospital - a Clinical Trial. 2010 June. PMID: NCT01155856. [Irrelevant patient (age, medical condition)].
300 French Pulmonary S. [Non-invasive positive pressure ventilation for neuromuscular diseases. Practice guidelines]. Revue des Maladies Respiratoires. 2006 Nov;23(5 Pt 4):14S5–S40. PMID: 17151547. [Foreign language study].17151547
301 Fried TR, Vaz Fragoso CA, Rabow MW. Caring for the older person with chronic obstructive pulmonary disease. JAMA - Journal of the American Medical Association. 2012 19 Sep;308(12):1254–63. PMID: 365686435. [Irrelevant study design].23011715
302 Frost F, Al-Hakim B, Wordingham-Baker S, . Inpatient adjustment of sub-optimal home mechanical ventilation (HMV)-an effective use of resources? Thorax. 2015 December;70:A174. PMID: 72199776. [Abstract/conference proceeding].
303 Fundació Institut de Recerca de l’Hospital de la Santa Creu i Sant P. Home Mechanical Ventilation Effectiveness and Air Leaks. 2006 June. PMID: NCT01090986. [Irrelevant study design].
304 Fundació Institut de Recerca de l’Hospital de la Santa Creu i Sant P. Home Mechanical Ventilation in Patients With Chronic Obstructive Pulmonary Disease (COPD) and Hypercapnic Response. 2005 October. PMID: NCT01120574. [Completed Clinical Trial].
305 Furlanetto KC, Pitta F. Oxygen therapy devices and portable ventilators for improved physical activity in daily life in patients with chronic respiratory disease. Expert Review of Medical Devices. 2017 Feb;14(2):103–15. PMID: 28116924. [Irrelevant patient (age, medical condition)].28116924
306 Gacouin A, Desrues B, Lena H, . Long-term nasal intermittent positive pressure ventilation (NIPPV) in sixteen consecutive patients with bronchiectasis: a retrospective study. European Respiratory Journal. 1996 Jun;9(6):1246–50. PMID: 8804945. [Irrelevant comparison or no comparison].8804945
307 Gacouin A, Leveiller G, Guy T, . [Long term survival in chronic obstructive pulmonary disease after ventilation in intensive care]. Revue des Maladies Respiratoires. 2009 Mar;26(3):257–65. PMID: 19367199. [Foreign language study].19367199
308 Galavotti V, Idotta G, Garuti G. Respiratory home care: Position paper. [Italian]. Rassegna di Patologia dell’Apparato Respiratorio. 2010 April;25(2):84–101. PMID: 359027072. [Foreign language study].
309 Galli JA, Krahnke JS, Mamary AJ, . Home non-invasive positive pressure ventilation use after an acute exacerbation of COPD with hypercapnic respiratory failure reduces six month readmission rate and mortality. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2013;187(no pagination). PMID: 71980825. [Abstract/conference proceeding].
310 Garguilo M, Leroux K, Lejaille M, . Patient-controlled positive end-expiratory pressure with neuromuscular disease: effect on speech in patients with tracheostomy and mechanical ventilation support. Chest. 2013 May;143(5):1243–51. PMID: 23715608. [Irrelevant intervention (or time frame)].23715608
311 Garner D, Naughton M, Berlowitz D, . The Novanz study - Non-invasive domiciliary ventilation in Australia and New Zealand. Journal of Sleep Research. 2011 October;20:64. PMID: 70586143. [Abstract/conference proceeding].
312 Garner DJ, Berlowitz DJ, Douglas J, . Home mechanical ventilation in Australia and New Zealand. European Respiratory Journal. 2013 Jan;41(1):39–45. PMID: 22653765. [Outcomes not reported per device intervention].22653765
313 Garner DJ, Naughton MA, Berlowitz D, . Domiciliary non-invasive ventilation in Australia and New Zealand. Respirology. 2011 April;16:30. PMID: 70383016. [Abstract/conference proceeding].
314 Garuti G, Bagatti S, Verucchi E, . Pulmonary rehabilitation at home guided by telemonitoring and access to healthcare facilities for respiratory complications in patients with neuromuscular disease. European journal of physical & rehabilitation medicine. 2013 Feb;49(1):51–7. PMID: 22820817. [Irrelevant study design].22820817
315 Garuti G. Home rehabilitation and therapy. [Italian]. Rassegna di Patologia dell’Apparato Respiratorio. 2010 April;25(2):76–7. PMID: 359027068. [Foreign language study].
316 Gasperini M, Clini E, Zaccaria S. Mechanical ventilation in chronic respiratory insufficiency: report on an Italian nationwide survey. The Italian Telethon Committee and the AIPO Study Group on Pulmonary Rehabilitation and Intensive Care. Monaldi Archives for Chest Disease. 1998 Aug;53(4):394–9. PMID: 9828593. [Irrelevant study design].9828593
317 Georges M, Adler D, Contal O, . Reliability of Apnea-Hypopnea Index Measured by a Home Bi-Level Pressure Support Ventilator Versus a Polysomnographic Assessment. Respiratory Care. 2015 Jul;60(7):1051–6. PMID: 25737571. [Irrelevant intervention (or time frame)].25737571
318 Georges M, Golmard J-L, Llontop C, . Initiation of non-invasive ventilation in amyotrophic lateral sclerosis and clinical practice guidelines: Single-centre, retrospective, descriptive study in a national reference centre. Amyotrophic Lateral sclerosis & Frontotemporal Degeneration. 2017 Feb;18(1-2):46–52. PMID: 27978772. [Irrelevant study design].27978772
319 Georges M, Golmard JL, Llontop C, . Initiation of non-invasive ventilation in amyotrophic lateral sclerosis and clinical practice guidelines: Single-centre, retrospective, descriptive study in a national reference centre. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2017;18(1-2):46–52. [Irrelevant study design].27978772
320 Georgescu M, Tanoubi I, Fortier LP, . Efficacy of preoxygenation with non-invasive low positive pressure ventilation in obese patients: crossover physiological study. Annales Francaises d Anesthesie et de Reanimation. 2012 Sep;31(9):e161–5. PMID: 22770916. [Irrelevant intervention (or time frame)].22770916
321 Gerard M, Robert D, Salamand J. Study of survival in 150 tracheotomized patients with chronic respiratory disease treated with assisted ventilation at home. Lyon Medical. 1981;245(8):555–8. [Published before 1995].
322 Gildeh N, Kindred J, Banerjee S. Improving the efficiency and patient experience using Telemodems for set-up of domiciliary non-invasive ventilation in a district general hospital. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72106000. [Abstract/conference proceeding].
323 Gillis-Haegerstrand C, Markstrom A, Barle H. Bi-level positive airway pressure ventilation maintains adequate ventilation in post-polio patients with respiratory failure. Acta Anaesthesiologica Scandinavica. 2006 May;50(5):580–5. PMID: 16643228. [Irrelevant intervention (or time frame)].16643228
324 Ginies G, Choutet P, Lamisse F, . Ventilatory assistance at home: procedure and future perspectives. Revue de Medecine de Tours. 1977;11(2):178–83. [Published before 1995].
325 Girault C. Noninvasive ventilation and acute respiratory failure. [French]. Revue des Maladies Respiratoires. 2005 November;22(5 C2):6S159–6S66. PMID: 44567943. [Foreign language study].
326 Gn YM, Moses R, Vyas A. The use of remote monitoring to assess ventilator adherence and outcomes within a regional home mechanical ventilation service. Thorax. 2016 December;71:A34–A5. PMID: 615030621. [Abstract/conference proceeding].
327 Goldstein R. Evaluating the end-stage patient for appropriate oxygen delivery system and identifying appropriate candidates for home ventilation. Seminars in Respiratory and Critical Care Medicine. 1996;17(6):477–89. PMID: 27045149. [Irrelevant patient (age, medical condition)].27045149
328 Goldstein RS, Psek JA, Gort EH. Home mechanical ventilation: Demographics and user perspectives. Chest. 1995;108(6):1581–6. PMID: 25368453. [Irrelevant comparison or no comparison].7497765
329 Golish J, Ioachimescu OC. Ambulatory titration of continuous positive airway pressure was as effective as polysomnography for obstructive sleep apnoea. Evidence-Based Medicine. 2007 October;12(5):148. PMID: 47611221. [Abstract/conference proceeding].17909239
330 Gomez JFS, Pacheco VA, Fernandez AGB, . Results of non invasive ventilation in patients with acute hypercapnic ventilatory failure and obesity hypoventilation syndrome (OHS). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923968. [Abstract/conference proceeding].
331 Goncalves M, Moreira J, Barros LS, . Addition of PEEP/EPAP during nocturnal Non-invasive ventilation in patients with severe restrictive disorders: Physiological effects and tolerance in a randomized pilot study. European respiratory journal. 2011 Respiratory Society Annual Congress 2011 Amsterdam Netherlands;38(no pagination):CONFERENCE START: 2011 Sep 24 CONFERENCE END: Sep 28. PMID: CN-01163572 NEW. [Abstract/conference proceeding].
332 Gonzalez L. Extubation in the home: Review of cases and guidelines of the process (505) (advanced). Journal of Pain and Symptom Management. 2011 January;41 (1):257. PMID: 70382557. [Irrelevant study design].
333 Goncalves Mr, Bach JR, Ishikawa Y, . Continuous noninvasive ventilatory support outcomes for neuromuscular disease: a multicenter collaboration and literature review. Pulmonology. 2018;24 [Epub ahead of print] [Article not available].
334 Gonzalez M, Serra L, Descalzi F, . Unattended home titration of adaptive pressure support servo-ventilation. Sleep Medicine. 2009 December;10:S21. PMID: 70238231. [Abstract/conference proceeding].
335 Gonzalez MM, Parreira VF, Rodenstein DO. Non-invasive ventilation and sleep. Sleep Med Rev. 2002 Feb;6(1):29–44. PMID: 12531140. [Irrelevant patient (age, medical condition)].12531140
336 Gonzalez MM, Parreira VF, Rodenstein DO. Non-invasive ventilation and sleep. Sleep Med Rev. 2002 Feb;6(1):29–44. PMID: 12531140. [Irrelevant patient (age, medical condition)].12531140
337 Gonzalez Rodriguez CI, Jimenez Bermejo F, Rubio T, . [Non-invasive home mechanical ventilation in the COPD patient]. Anales del Sistema Sanitario de Navarra. 2005 Sep-Dec;28(3):345–50. PMID: 16421612. [Foreign language study].16421612
338 Gonzalez-Bermejo J, Godard M, Duguet A, . Removal of a tracheostomy in ventilator-dependent patients with neuromuscular disease. [French]. Revue des Maladies Respiratoires. 2005 November;22(5):731–7. PMID: 44064156. [Foreign language study].16272975
339 Gonzalez-Bermejo J, Lofaso F, Falaize L, . Resting energy expenditure in Duchenne patients using home mechanical ventilation. European Respiratory Journal. 2005 Apr;25(4):682–7. PMID: 15802343. [Irrelevant comparison or no comparison].15802343
340 Gonzalez-Bermejo J, Morelot-Panzini C, Arnol N, . Impact of the quality of non-invasive ventilation on the one-year mortality of patients with amyotrophic lateral sclerosis. Amyotrophic Lateral Sclerosis. 2011 November;12:64. PMID: 70595731. [Abstract/conference proceeding].
341 Gonzalez-Bermejo J, Morelot-Panzini C, Dorsett J, . The survival of amyotrophic lateral sclerosis patients placed under non invasive ventilation (NIV) does not depend on the ventilatory mode used (volume vs.pressure NIV). Amyotrophic Lateral Sclerosis. 2011 November;12:63–4. PMID: 70595730. [Abstract/conference proceeding].
342 Gouda P, Chua J, Langan D, . A decade of domiciliary non-invasive ventilation in the west of Ireland. Irish Journal of Medical Science. 2017 May;186(2):505–10. PMID: 27744642. [Irrelevant comparison or no comparison].27744642
343 Gozal D. Nocturnal ventilatory support in patients with cystic fibrosis: comparison with supplemental oxygen. European Respiratory Journal. 1997 Sep;10(9):1999–2003. PMID: 9311492. [Irrelevant outcome].9311492
344 Group CW. Noninvasive positive pressure ventilation for chronic respiratory failure patients with stable chronic obstructive pulmonary disease (COPD): an evidence-based analysis. Ontario health technology assessment series. 2012;12(9):1. [Irrelevant study design].
345 Guan L, Wu W, Huo Y, . Efficacy of bilevel positive airway pressure and continuous positive airway pressure therapy in patients with obesity hypoventilation syndrome: protocol for systematic review and meta-analysis. BMJ Open. 2018 May 03;8(5):e020832. PMID: 29724743. [Irrelevant study design].29724743
346 Gruis KL, Chernew ME, Brown DL. The cost-effectiveness of early noninvasive ventilation for ALS patients. BMC health services research. 2005;5(1):58. [Irrelevant outcome].16131401
347 Guber A, Morris E, Chen B, . First experience with the home-care management system for respiratory patients in Israel. Israel Medical Association Journal. 2002;4(6):418–20. PMID: 34624715. [Irrelevant patient (age, medical condition)].12073412
348 Guidelines for the clinical management of COPD. Oxygen therapy and long-term ventilatory assistance. [French]. Revue des maladies respiratoires. 2003 Jun;20(3 Pt 2):S50–3. PMID: 137613046. [Foreign language study].
349 Guilleminault C, Philip P, Robinson A. Sleep and neuromuscular disease: bilevel positive airway pressure by nasal mask as a treatment for sleep disordered breathing in patients with neuromuscular disease. Journal of Neurology, Neurosurgery & Psychiatry. 1998 Aug;65(2):225–32. PMID: 9703177. [Outcomes not reported per device intervention].9703177
350 Gulati A, Ali M, Oscroft N, . A randomised trial of autovariable positive airway pressure vs standard non-invasive ventilation in patients with COPD with chronic ventilatory failure. Thorax. 2009 December;64:A29. PMID: 70254442. [Abstract/conference proceeding].
351 Gungor G, Karakurt Z, Berk Takir H, . Patients with chronic hypercapnic respiratory failure using home noninvasive mechanical ventilation: Is it better for pulmonary performance? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71840856. [Abstract/conference proceeding].
352 Gustafson T, Franklin KA, Midgren B, . Survival of patients with kyphoscoliosis receiving mechanical ventilation or oxygen at home. Chest. 2006 Dec;130(6):1828–33. PMID: 17167004. [Irrelevant intervention (or time frame)].17167004
353 Haarmann H, Folle J, Nguyen XP, . Impact of Non-Invasive Ventilation on Sympathetic Nerve Activity in Chronic Obstructive Pulmonary Disease. Lung. 2017;195(1):69–75. [Irrelevant outcome].27853876
354 Halpin DM. Global Initiative for Chronic Obstructive Lung Disease (GOLD) Guidelines. Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Lung Disease: NHLBI/WHO Workshop Report. Proc Am Thorac Soc. 2006;3(3):227–33. [Irrelevant study design].16636090
355 Hamouda Z, Nakee S, M’Ghirbi A, . Long-term home non-invasive ventilation (NIV) following hypercapnic respiratory failure requiring mechanical ventilation: Results of 10 years practice intensive care unit of Monastir. Annals of Intensive Care. 2017 January;7 (1 Supplement 1):57. PMID: 614625583. [Abstract/conference proceeding].28560683
356 Han L, Wang Y, Gan Y, . Effects of adaptive support ventilation and synchronized intermittent mandatory ventilation on peripheral circulation and blood gas markers of COPD patients with respiratory failure. Cell Biochemistry & Biophysics. 2014 Sep;70(1):481–4. PMID: 24748176. [Irrelevant intervention (or time frame)].24748176
357 Hannan LM, Sahi H, Road JD, . Care Practices and Health-related Quality of Life for Individuals Receiving Assisted Ventilation. A Cross-National Study. Annals of the American Thoracic Society. 2016 Jun;13(6):894–903. PMID: 27295155. [Irrelevant outcome].27295155
358 Hannan LM, Whitehurst DGT, Bryan S, . Framing of mobility items: a source of poor agreement between preference-based health-related quality of life instruments in a population of individuals receiving assisted ventilation. Quality of Life Research. 2017 Jun;26(6):1493–505. PMID: 28255744. [Irrelevant study design].28255744
359 Hannover Medical S. Long-Term Study On Home Spirometry After Lung Transplantation. 2000 January. PMID: NCT00743171. [Irrelevant patient (age, medical condition)].
360 Hardinge M, Annandale J, Bourne S, . British Thoracic Society guidelines for home oxygen use in adults: accredited by NICE. Thorax. 2015;70:(Suppl 1):i1–i43.[Irrelevant outcome].25870317
361 Hart D, O’Dochartaigh C, Beaumont-Orr S, . The effects of heated humidification in patients on non-invasive ventilation (NIV) for acute respiratory failure. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841395. [Abstract/conference proceeding].
362 Hart DE, Corna NE. Investigation of the incidence and effect of tubing condensate during bi-level ventilation in the home. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2011;183(1 MeetingAbstracts). PMID: 70846606. [Abstract/conference proceeding].
363 Hart DE, Corna NE. Investigation of the incidence and effect of tubing condensate during bi-level ventilation in the home. Respirology. 2012 April;17:87. PMID: 70705119. [Abstract/conference proceeding].21943039
364 Hartl SE, Heindl W, Lahrmann H, . Equipment for long-term ventilated patients at home. Concensus recommendations of the Austrian Society of Lung Diseases and Tuberculosis. [German]. Wiener Klinische Wochenschrift, Supplement. 2004;116(3):1–20. PMID: 38937762. [Foreign language study].
365 Haute Aurorite de S. [Recommendations of HAS: Practical issues in home non-invasive ventilation in patients with neuromuscular disease]. Revue des Maladies Respiratoires. 2006 Sep;23:(4 Suppl):13S153–5. PMID: 17057641. [Foreign language study].17057641
366 Hazenberg A, Kerstjens H, Wijkstra P. Is home mechanical ventilation really effective in patients with amyotrophic lateral scleroses? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780066. [Abstract/conference proceeding].
367 Hazenberg A, Kerstjens HAM, Prins SCL, . Initiation of chronic ventilatory support at home, by using telemonitoring, is effective and saves costs. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849031. [Abstract/conference proceeding].
368 Hazenberg A, Kerstjens HAM, Prins SCL, . Is chronic ventilatory support really effective in patients with amyotrophic lateral sclerosis? Journal of Neurology. 2016 Dec;263(12):2456–61. PMID: 27638636. [Irrelevant intervention (or time frame)].27638636
369 Hein H, Rasche K, Wiebel M, . [Recommendations for home and long-term ventilation]. Medizinische Klinik. 2006 Feb 15;101(2):148–52. PMID: 16501912. [Foreign language study].16501912
370 Hein H, Schucher B, Kirsten D, . [Prospective study of the quality of life in intermittent self-ventilation]. Medizinische Klinik. 1997 Apr 28;92 Suppl 1:93–4. PMID: 9235486. [Foreign language study].9235486
371 Herala M, Stalenheim G, Boman G. Effects of positive expiratory pressure (PEP), continuous positive airway pressure (CPAP) and hyperventilation in COPD patients with chronic hypercapnea. Upsala Journal of Medical Sciences. 1995;100(3):223–32. PMID: 8808185. [Irrelevant intervention (or time frame)].8808185
372 Heinemann F, Budweiser S, Dobroschke J, . Non-invasive positive pressure ventilation improves lung volumes in the obesity hypoventilation syndrome. Respiratory medicine. 2007;101(6):1229–35. [Irrelevant comparison or no comparison].17166707
373 Hida W, Okabe S, Tatsumi K, . Nasal continuous positive airway pressure improves quality of life in obesity hypoventilation syndrome. Sleep & Breathing. 2003 Mar;7(1):3–12. PMID: 12712392. [Irrelevant patient (age, medical condition)].12712392
374 Hidalgo Carvajal R, Sanchez Casado M, e Miguel-Diez J, . Beneficial effect of nocturnal oximetric control on the clinical and gasometric situation and the prognosis of patients with home non-invasive mechanical ventilation. Medicina Clinica. 2018 Feb 28;28:28. PMID: 29501436. [Foreign language study].29501436
375 High Flow Nasal Cannula vs NPPV in Moderate Chronic Obstructive Pulmonary Disease Exacerbation. Https://clinicaltrials.gov/show/nct03014869. 2017. PMID: CN-01561123 NEW. [Irrelevant patient (age, medical condition)].
376 Highcock MP, Morrish E, Jamieson S, . An overnight comparison of two ventilators used in the treatment of chronic respiratory failure. Thorax. 2000;55(SUPPL. 3). [Abstract/conference proceeding].
377 Highcock MP, Shneerson JM, Smith IE. Increased ventilation with NiIPPV does not necessarily improve exercise capacity in COPD. European Respiratory Journal. 2003 Jul;22(1):100–5. PMID: 12882458. [Irrelevant intervention (or time frame)].12882458
378 Highcock MP, Smith IE, Shneerson JM. The effect of noninvasive intermittent positive-pressure ventilation during exercise in severe scoliosis. Chest. 2002 May;121(5):1555–60. PMID: 12006443. [Irrelevant intervention (or time frame)].12006443
379 Hilbert G, Vargas F, Valentino R, . Noninvasive ventilation in acute exacerbations of chronic obstructive pulmonary disease in patients with and without home noninvasive ventilation. Critical Care Medicine. 2002;30(7):1453–8. PMID: 34756224. [Irrelevant setting/location].12130961
380 Hodgson LE, Murphy PB. Update on clinical trials in home mechanical ventilation. Journal of Thoracic Disease. 2016 Feb;8(2):255–67. PMID: 26904266. [Irrelevant study design].26904266
381 Hopkinson NS, Sharshar T, Dayer MJ, . The effect of acute non-invasive ventilation on corticospinal pathways to the respiratory muscles in chronic obstructive pulmonary disease. Respiratory Physiology and Neurobiology. 2012 31 Jul;183(1):41–7. PMID: 365170315. [Irrelevant outcome].22652437
382 Hospitales Universitarios Virgen del R, Fondo de Investigacion S. Non Invasive Mechanical Ventilation Versus Respiratory Rehabilitation in Hypercapnic COPD. 2006 March. PMID: NCT01377818. [Completed Clinical Trial].
383 Howard M, Berlowitz D, Batchelder I, . Day implementation model for non-invasive ventilation in motor neurone disease. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2010;181(1 MeetingAbstracts). PMID: 70840512. [Abstract/conference proceeding].
384 Howard M, Piper A, Stevens B, . A randomised controlled trial of CPAP vs non-invasive ventilation for initial treatment of obesity hypoventilation syndrome. Respirology. 2015 March;20:52. PMID: 71870731. [Abstract/conference proceeding].
385 Howard M. The evidence for domiciliary noninvasive ventilation. Sleep and Biological Rhythms. 2009 October;7:A9. PMID: 70206711. [Irrelevant study design].
386 Howard RS, Wiles CM, Hirsch NP, . Respiratory involvement in primary muscle disorders: Assessment and management. Quarterly Journal of Medicine. 1993;86(3):175–89. PMID: 23120813. [Published before 1995].8483991
387 Howard RS. Respiratory failure because of neuromuscular disease. Current Opinion in Neurology. 2016 Oct;29(5):592–601. PMID: 27427990. [Irrelevant study design].27427990
388 Hu Z-Y, Han J-Y, Wang S-J, . [Clinical value of noninvasive intermittent positive-pressure ventilation in pneumoconiosis combined with respiratory failure]. Zhonghua Lao Dong Wei Sheng Zhi Ye Bing Za Zhi/Zhonghua Laodong Weisheng Zhiyebing Zazhi/Chinese Journal of Industrial Hygiene & Occupational Diseases. 2011 Apr;29(4):311–3. PMID: 21941790. [Foreign language study].21941790
389 Huang HB, Xu B, Liu GY, . Use of noninvasive ventilation in immunocompromised patients with acute respiratory failure: A systematic review and meta-analysis. Critical Care. 2017;21(1). [Irrelevant setting/location].
390 Hui DSC. Nocturnal nasal positive pressure ventilation for chronic obstructive pulmonary disease. Hong Kong Medical Journal. 2007 October;13(5 Supplement 5):37–41. PMID: 610342979. [Irrelevant comparison or no comparison].
391 Huttmann SE, Storre JH, Windisch W. [Home mechanical ventilation: Invasive and noninvasive ventilation therapy for chronic respiratory failure]. Anaesthesist. 2015 Jun;64(6):479–86; quiz 87. PMID: 26065554. [Foreign language study].26065554
392 Icadom PR. Wearable Noninvasive Positive Pressure Ventilation Device in COPD. 2017 January. PMID: NCT03130361. [Irrelevant study design].
393 Idell S. Managing end-stage COPD with positive-pressure ventilation. Journal of Critical Illness. 1998;13(12):731–4. PMID: 29279822. [Abstract/conference proceeding].29279822
394 Imperial College L, The Health F. Assessment of the Effects of an Intermediate Care Package in Preventing Hospitalisation of Patients With COPD. 2003 December. PMID: NCT00129779. [Irrelevant intervention (or time frame)].
395 Inayat B, Werpachowska A, Howard M, . Comparison of Wye Valley Trust motor neurone disease (MND) integrated care pathway with current NICE guidelines and monitoring of domiciliary non-invasive ventilation (NIV) via wireless modem. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780186. [Abstract/conference proceeding].
396 Intermittent positive pressure breathing therapy of chronic obstructive pulmonary disease. A clinical trial. Annals of internal medicine. 1983 Nov;99(5):612–20. PMID: CN-00032786 UPDATE. [Published before 1995].6357018
397 Islem O, Kmar H, Ali A, . Impact of anemia in long term prognosis of patients with COPD exacerbations. Annals of Intensive Care. Conference: French Intensive Care Society, International Congress Reanimation. 2018;8(1 Supplement 1). PMID: 620836878. [Abstract/conference proceeding].
398 Ishikawa Y, Miura T, Ishikawa Y, . Duchenne muscular dystrophy: survival by cardio-respiratory interventions. Neuromuscular Disorders. 2011;21(1):47–51. [Irrelevant patient (age, medical condition)].21144751
399 Iwashita H, Imai H, Namba R, . A guideline for the management of als in national hospitals. IRYO - Japanese Journal of National Medical Services. 2000;54(12):584–6. [Foreign language study].
400 Jackson M, Smith I, King M, . Long term non-invasive domiciliary assisted ventilation for respiratory failure following thoracoplasty. Thorax. 1994 Sep;49(9):915–9. PMID: 7940434. [Published before 1995].7940434
401 Jager L, Franklin KA, Midgren B, . Increased survival with mechanical ventilation in posttuberculosis patients with the combination of respiratory failure and chest wall deformity. Chest. 2008 Jan;133(1):156–60. PMID: 18071021. [Unclear device].18071021
402 Janssens JP, Cicotti E, Fitting JW, . Non-invasive home ventilation in patients over 75 years of age: tolerance, compliance, and impact on quality of life. Respiratory Medicine. 1998 Dec;92(12):1311–20. PMID: 10197223. [Irrelevant study design].10197223
403 Janssens J-P, Derivaz S, Breitenstein E, . Changing patterns in long-term noninvasive ventilation: a 7-year prospective study in the Geneva Lake area. Chest. 2003 Jan;123(1):67–79. PMID: 12527605. [Outcomes not reported per device intervention].12527605
404 Janssens JP, Kehrer P, Chevrolet JC, . [Non-invasive home ventilation (NIHV): long-term survival of 32 cases]. Revue des Maladies Respiratoires. 1999 Sep;16(4):511–20. PMID: 10549061. [Foreign language study].10549061
405 Janssens J-P, Metzger M, Sforza E. Impact of volume targeting on efficacy of bi-level non-invasive ventilation and sleep in obesity-hypoventilation. Respiratory Medicine. 2009 Feb;103(2):165–72. PMID: 18579368. [Irrelevant intervention (or time frame)].18579368
406 Janssens JP, Penalosa B, Degive C, . Quality of life of patients under home mechanical ventilation for restrictive lung diseases: a comparative evaluation with COPD patients. Monaldi Archives for Chest Disease. 1996 Jun;51(3):178–84. PMID: 8766189. [Outcomes not reported per device intervention].8766189
407 Japanese Society of Pulmonary M, Japanese Society of Respiratory Disease M. [Treatments for chronic respiratory failure]. Nihon Kokyuki Gakkai Zasshi. 2006 Jul;Suppl:18–21. PMID: 1698665516986655. [Foreign language study].
408 Jaye J, Chatwin M, Morrell MJ, . A randomized trial of autotitrated non-invasive ventilation (NIV) v standard NIV, impact on sleep quality and nocturnal hypoventilation in restrictive disorders [Abstract]. American Thoracic Society International Conference, May. 2008. PMID: CN-00679303 UPDATE. [Abstract/conference proceeding].
409 Jennum P. Mortality of obesity hypoventilation with and without CPAP Treatment: A controlled national study. Sleep Medicine. 2013 December;14:e160–e1. PMID: 71306377. [Abstract/conference proceeding].
410 Johnson O, Rodger J, Robertson A. Home initiation of non-invasive ventilation for motor neurone disease. Amyotrophic Lateral Sclerosis. 2009;10:59–60. PMID: 70078385. [Abstract/conference proceeding].
411 Jolliet P, Besbes L, Abroug F, . An international phase iii randomised trial on the efficacy of helium/oxygen during spontaneous breathing and intermittent non-invasive ventilation for severe exacerbations of chronic obstructive pulmonary disease (The E.C.H.O.<sup>ICU</sup> trial). Intensive Care Medicine Experimental. 2015;3(no pagination). PMID: CN-01211732 NEW. [Abstract/conference proceeding].
412 Jones DJM, Braid GM, Wedzicha JA. Nasal masks for domiciliary positive pressure ventilation: Patient usage and complications. Thorax. 1994;49(8):811–2. PMID: 24250242. [Published before 1995].8091329
413 Jones SE, Packham S, Hebden M, . Domiciliary nocturnal intermittent positive pressure ventilation in patients with respiratory failure due to severe COPD: Long term follow up and effect on survival. Thorax. 1998;53(6):495–8. PMID: 28308066. [Irrelevant intervention (or time frame)].9713450
414 Jónsdóttir B. IL-8 predicts early mortality in patients with acute hypercapnic respiratory failure treated with noninvasive positive pressure ventilation. BMC pulmonary medicine. 2017;17(1):35. [Irrelevant patient (age, medical condition)].28178959
415 Jothieswaran A, Mascareno M, Bokhari S, . Survival in patients with chronic type 2 respiratory failure: A comparison of obesity hypoventilation syndrome, COPD and overlap syndrome. Thorax. 2015 December;70:A172–A3. PMID: 72199773. [Abstract/conference proceeding].
416 Jounieaux V, Rodenstein DO. [Home mechanical ventilation: indications and pathophysiological limitations]. Revue des Maladies Respiratoires. 2004 Apr;21(2 Pt 1):358–66. PMID: 15211245. [Foreign language study].15211245
417 Kallus CE, Oldmixon CM. Clinical application of noninvasive ventilation. Nursing management. 2009 May;40(5):45–7. PMID: 355881306. [Irrelevant study design].
418 Kalra S, Bhattacharyya A, Mahar J, . Mechanical ventilation in ARDS patients with class iii obesity: Do we apply evidence-based management? Chest. 2017 October;152 (4 Supplement 1):A213. PMID: 619296527. [Abstract/conference proceeding].
419 Kamii Y, Matsui H, Hirose T, . Investigation of COPD patients discharged without home mechanical ventilation after in-hospital use of acute non-invasive ventilation. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614777296. [Abstract/conference proceeding].
420 Kaohsiung Medical University Chung-Ho Memorial H. The Efficacy of Pulmonary Rehabilitation Exercise in Home Care for the Non-invasive Ventilator-dependent Elderly With COPD. 2016 July. PMID: NCT02836912. [Completed Clinical Trial].
421 Karakurt S, Fanfulla F, Nava S. Is it safe for patients with chronic hypercapnic respiratory failure undergoing home noninvasive ventilation to discontinue ventilation briefly? Chest. 2001 May;119(5):1379–86. PMID: 11348942. [Irrelevant study design].11348942
422 Karakurt Z, Guven AO, Mocin OY, . Six minute walking distance in kyphoscoliosis patients with chronic respiratory failure. Multidisciplinary Respiratory Medicine. 2010 Aug 31;5(4):244–9. PMID: 22958538. [Irrelevant comparison or no comparison].22958538
423 Karakurt Z, Mocin OY, Adiguzel N, . Long term home mechanical ventilation: 9 year experience. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2011;38(no pagination). PMID: 72117301. [Abstract/conference proceeding].
424 Karg O, Geiseler J. Hot topics in COPD: Home mechanical ventilation - What are the facts?. [German]. Atemwegs- und Lungenkrankheiten. 2012 September;38(9):376–80. PMID: 365740504. [Foreign language study].
425 Karg O. Long-term home mechanical ventilation: Indications and results. Atemwegs- und Lungenkrankheiten. 2002;28(10):482–6. [Irrelevant study design].
426 Kate A, Sandeep HS, Chaudhari P, . BiPAP in advanced IPF: Hope for palliation? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923895. [Abstract/conference proceeding].
427 Katholieke Universiteit Leuven QsU, Kingston O. Effects of Inspiratory Muscle Training on Dyspnea Perception During Exercise in Patients With COPD. 2013 July. PMID: NCT01900873. [Irrelevant intervention (or time frame)].
428 Kaub-Wittemer D, Von Steinbuchel N, Wasner M, . Quality of life and psychosocial issues in ventilated patients with amyotrophic lateral sclerosis and their caregivers. Journal of Pain and Symptom Management. 2003 01 Oct;26(4):890–6. PMID: 37188465. [Irrelevant comparison or no comparison].14527757
429 Kaub-Wittemer D, Wasner M, Neudert C, . Quality of life aspects of home-ventilated patients with amyotrophic lateral sclerosis (ALS) and their family members. [German]. Journal fur Anasthesie und Intensivbehandlung. 2002;9(1):34–5. PMID: 34875226. [Foreign language study].
430 Keenan SP, Sinuff T, Burns KEA, . Clinical practice guidelines for the use of noninvasive positive-pressure ventilation and noninvasive continuous positive airway pressure in the acute care setting. Canadian Medical Association Journal. 2011;183(3):E195–E214. [Irrelevant setting/location].21324867
431 Keihani SM, Hillman D. Home non-invasive ventilation reduces hospitalisation. Sleep and Biological Rhythms. 2009 October;7:A38–A9. PMID: 70206779. [Abstract/conference proceeding].
432 Kennedy S. Case management guidelines for ventilator patients. Continuing Care. 1990 Jul;9(7):26–8. PMID: 10148141. [Irrelevant study design].10148141
433 Kettemann D, Funke A, Maier A, . Clinical characteristics and course of dying in patients with amyotrophic lateral sclerosis withdrawing from long-term ventilation. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2017 02 Jan;18(1-2):53–9. PMID: 611749697. [Irrelevant outcome].27534566
434 Khatun Y, Murphy PB, Davidson AC, . Seasonal variation in initiation and discontinuation of domiciliary non-invasive ventilation: A 12-month cohort study. Thorax. 2011 December;66:A179–A80. PMID: 70627584. [Abstract/conference proceeding].
435 Khilnani G, Saikia N, Sharma S, . Efficacy of non-invasive postiive pressure ventilation (NPPV) for management of COPD with acute or acute on chronic respiratory failure: A randomized controlled trial [abstract]. American journal of respiratory and critical care medicine. 2002;165:(8 Suppl):A387. PMID: CN-00383316 UPDATE. [Abstract/conference proceeding].
436 Kilger E, Pichier B, Felbinger TW, . Effects of noninvasive ventilation in the weaning from acute respiratory insufficiency. Critical Care Medicine. 1999;27(1 SUPPL.). [Abstract/conference proceeding].
437 Kim C-H, Kim MS. Ventilator use, respiratory problems, and caregiver well-being in korean patients with amyotrophic lateral sclerosis receiving home-based care. Journal of Neuroscience Nursing. 2014 Oct;46(5):E25–32. PMID: 25188688. [Irrelevant intervention (or time frame)].25188688
438 Kim DH, Kang S-W, Choi WA. Home mechanical ventilation in South Korea. Yonsei Medical Journal. 2014 Nov;55(6):1729–35. PMID: 25323913. [Irrelevant outcome].25323913
439 Kim RD, Kapur VK, Redline-Bruch J, . An Economic Evaluation of Home Versus Laboratory-Based Diagnosis of Obstructive Sleep Apnea. Sleep. 2015 Jul 01;38(7):1027–37. PMID: 26118558. [Irrelevant patient (age, medical condition)].26118558
440 Kimura F. Tracheostomy and invasive mechanical ventilation in amyotrophic lateral sclerosis: decision-making factors and survival analysis. Rinsho Shinkeigaku - Clinical Neurology. 2016 Apr 28;56(4):241–7. PMID: 27025993. [Foreign language study].27025993
441 King AC. Long-term home mechanical ventilation in the United States. Respiratory care. 2012;57(6):921–32. [Irrelevant study design].22663967
442 King AC. Long-term home mechanical ventilation in the United States. Respiratory care. 2012;57(6):921–32. [Irrelevant study design].22663967
443 Kinnear W, Colt J, Watson L, . Long-term non-invasive ventilation in muscular dystrophy: Trends in use over 25 years in a home ventilation unit. Chronic Respiratory Disease. 2017 01 Feb;14(1):33–6. PMID: 614696261. [Irrelevant comparison or no comparison].27330037
444 Kinnear W, Watson L, Smith P, . Effect of expiratory positive airway pressure on tidal volume during non-invasive ventilation. Chronic Respiratory Disease. 2017 May;14(2):105–9. PMID: 27923982. [Irrelevant outcome].27923982
445 Kitajima T, Marumo S, Shima H, . Clinical impact of episodic nocturnal hypercapnia and its treatment with noninvasive positive pressure ventilation in patients with stable advanced COPD. International Journal of Copd. 2018;13:843–53. PMID: 29563784. [Irrelevant comparison or no comparison].29563784
446 Kjellberg J, Jennum P. The consequences of snoring, obstructive sleep apnoea and obesity hypoventilation syndrome on mortality, social outcome, economy and effect of CPAP treatment. A controlled national study. European Journal of Neurology. 2010 September;17:616. PMID: 70275093. [Abstract/conference proceeding].
447 Klang B, Markstrom A, Sundell K, . Hypoventilation does not explain the impaired quality of sleep in postpolio patients ventilated noninvasively vs. invasively. Scandinavian Journal of Caring Sciences. 2008 Jun;22(2):236–40. PMID: 18489694. [Irrelevant comparison or no comparison].18489694
448 Kofler AM, Carlesi A, Cutrera R, . BiPAP versus PEP as chest physiotherapy in patients with cystic fibrosis [abstract]. Pediatric pulmonology. 1998;26:(Suppl 17):344. PMID: CN-00291400 UPDATE. [Irrelevant patient (age, medical condition)].9859904
449 Koga T, Watanabe K, Sano M, . Breathing intolerance index: A new indicator for ventilator use. American Journal of Physical Medicine and Rehabilitation. 2006 January;85(1):24–30. PMID: 43004851. [Irrelevant intervention (or time frame)].16357545
450 Kogo M, Nakagawa A, Kawachi H, . The effect of introducing home NPPV in patients following acute hypercapnic respiratory failure due to chronic respiratory disorder. Respirology. 2017 November;22 (Supplement 3):125. PMID: 619967661. [Abstract/conference proceeding].
451 Kohler D, Criee CP, Raschke F. [Guidelines for home oxygen and home ventilation therapy. German Society of Pneumology, German Society of Sleep Medicine, Working Group of Nocturnal Respiratory and Cardiovascular Disorders, Working Circle of Home and Long-Term Ventilation]. Medizinische Klinik. 1997 Jan 15;92(1):2–6. PMID: 9121410. [Foreign language study].9121410
452 Kohler D, Criee CP, Raschke F. Guidelines for treatment with oxygen and ventilation at home. [German]. Medizinische Klinik. 1997 15 Jan;92(1):2–6. PMID: 27086383. [Foreign language study].27086383
453 Kohnlein T. Non-invasive ventilation at home in severe stable hypercapnic COPD. [German]. Atemwegs- und Lungenkrankheiten. 2016 April;42(4):220–5. PMID: 610436685. [Foreign language study].
454 Köhnlein T. Non-invasive ventilation at home in severe stable hypercapnic COPD. Atemwegs- und Lungenkrankheiten. 2016;42(4):220–5. [Foreign language study].
455 Kompalitch M, Brille D, Diaz M, . [A control trial of home I.P.P.B. therapy in patients with chronic obstructive respiratory insufficiency. Protocol and state of the study (author’s transl)]. Revue Francaise des Maladies Respiratoires. 1979 Jul-Aug;7(4):429–32. PMID: 121483. [Published before 1995].121483
456 Kompalitch M, Diaz M, Abdelaoui A. The treatment of severe respiratory insufficiencies of restrictive type by intermittent positive pressure breathing at home. Revue Francaise des Maladies Respiratoires. 1977;5(4):458–60. [Foreign language study].
457 Koschel D, Handhziev S, Stiller O, . Non-invasive home ventilation in chronic exogen-allergic alveolitis. [German]. Allergologie. 2008 November;31(11):493–4. PMID: 352743642. [Foreign language study].
458 Kotecha S, Buchan C, Parker K, . Domiciliary non-invasive ventilation post lung transplantation. Respirology. 2018 Jan;23(1):96–9. PMID: 28840631. [Irrelevant intervention (or time frame)].28840631
459 Kotecha S, Buchan C, Parker K, . Domicillary non-invasive ventilation post lung transplantation. Sleep and Biological Rhythms. 2015 October;13:84. PMID: 72072128. [Abstract/conference proceeding].
460 Krahnke JS, Galli J, Shenoy KV, . Noninvasive positive pressure ventilation use in acute exacerbation of copd after hospitalization for hypercapnic respiratory failure may decrease 30 day readmission. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2012;185(no pagination). PMID: 71987632. [Abstract/conference proceeding].
461 Krahnke JS, Galli JA, Mamary AJ, . Home non-invasive positive pressure ventilation use COPD hospitalization with hypercapnic respiratory failure in patients with overlap syndrome reduces six-month readmission rate. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2013;187(no pagination). PMID: 71983886. [Abstract/conference proceeding].
462 Krempf M, Barel P, Adoue D, . [Application of residual positive pressure during assisted ventilation at home using pressure relaxator devices (author’s transl)]. Revue Francaise des Maladies Respiratoires. 1979 Jul-Aug;7(4):387–9. PMID: 398559. [Foreign language study].398559
463 Kruse N, Bulow HH. Noninvasive ventilation of patients with respiratory insufficiency: Six months experience. [Danish]. Ugeskrift for Laeger. 2003 13 Oct;165(42):4020–5. PMID: 38113490. [Foreign language study].14610836
464 Kumar SI, Doo K, Sottilo-Brammeier J, . Super Obesity in the Medical Intensive Care Unit. Journal of Intensive Care Medicine. 2018. PMID: 621402205621402205. [Irrelevant intervention (or time frame)].
465 Kurek CJ, Dewar D, Lambrinos J, . Clinical and economic outcome of mechanically ventilated patients in New York State during 1993: analysis of 10,473 cases under DRG 475. Chest. 1998 Jul;114(1):214–22. PMID: 9674472. [Irrelevant study design].9674472
466 Kyle UG, Janssens JP, Rochat T, . Body composition in patients with chronic hypercapnic respiratory failure. Respiratory Medicine. 2006 February;100(2):244–52. PMID: 43078975. [Irrelevant outcome].15927457
467 Kyoto University GSoM, Ministry of Health L, Welfare J. Prognosis in Patients With Chronic Respiratory Failure Receiving Domiciliary Noninvasive Positive Pressure Ventilation (NPPV). 2009 April. PMID: NCT00905476. [Completed Clinical Trial].
468 L Goulart C, San Martin EA, Mansour KMK, . Influence of expiratory positive airway pressure on cardiac autonomic modulation at rest and in submaximal exercise in COPD patients. Brazilian Journal of Medical & Biological Research. 2018;51(6):e7180. PMID: 29694504. [Irrelevant intervention (or time frame)].29694504
469 Laakso K, Markstrom A, Idvall M, . Communication experience of individuals treated with home mechanical ventilation. International Journal of Language & Communication Disorders. 2011 Nov-Dec;46(6):686–99. PMID: 22026570. [Irrelevant comparison or no comparison].22026570
470 Laier-Groeneveld G, Anderer H, Bansch S, . [Guidelines for equipment needs in home ventilation. Home and Long-term Ventilation Study Group]. Medizinische Klinik. 1995 Jun 15;90(6):321–3. PMID: 7637662. [Foreign language study].7637662
471 Laier-Groeneveld G, Criee CP. The long-term effects of non-invasive intermittent self-ventilation in patients with chronic obstructive lung disease. [German]. Atemwegs- und Lungenkrankheiten. 1994;20(6):340–1. PMID: 24222769. [Published before 1995].24222769
472 Laier-Groeneveld G. [Guidelines for indications and implementation of intermittent artificial self-ventilation. “Working Group for Home and Long-Term Ventilation”]. Medizinische Klinik. 1993 Sep 15;88(9):509–10. PMID: 8232087. [Foreign language study].8232087
473 Laier-Groeneveld G. [Guidelines for management of home ventilation patients. Home and Long-Term Ventilation Working Group]. Medizinische Klinik. 1996 Oct 15;91(10):615–6. PMID: 9019637. [Foreign language study].9019637
474 Laier-Groeneveld G. [Home and Long-Term Ventilation Study Group: guidelines for equipment needed for home ventilation. Home and Long-Term Ventilation Study Group]. Pneumologie. 1996 Aug;50(8):532–4. PMID: 8975244. [Foreign language study].8975244
475 Laier-Groeneveld G. Guidelines for the use of respirators at home. [German]. Medizinische Klinik. 1996;91(10):615–6. PMID: 26361305. [Foreign language study].9019637
476 Lamia B, Cuvelier A, Benichou J, . [A multi-centre randomized controlled trial of domiciliary non-invasive ventilation vs long-term oxygen therapy in survivors of acute hypercapnic respiratory failure due to COPD. Non-invasive ventilation in obstructive lung disease (NIVOLD) study]. Revue des Maladies Respiratoires. 2012 Nov;29(9):1141–8. PMID: 23200590. [Foreign language study].23200590
477 Lane A, Harlow S, Murray P. A local domiciliary non-invasive ventilation (NIV) service reduces length of hospital stay for patients unable to wean from NIV. Thorax. 2015 December;70:A175. PMID: 72199778. [Abstract/conference proceeding].
478 Lane A, Tollit J, Lewis R, . Efficacy of a local domiciliary non-invasive ventilation (NIV) service for motor neurone disease (MND): Patient survival, safety and satisfaction. Thorax. 2015 December;70:A176. PMID: 72199779. [Abstract/conference proceeding].
479 Larsen UT, Juhl B. [Long-term respirator treatment]. Ugeskrift for Laeger. 1990 May 14;152(20):1428–31. PMID: 2111594. [Foreign language study].2111594
480 Laserna E, Barrot E, Beiztegui A, . [Non-invasive ventilation in kyphoscoliosis. A comparison of a volumetric ventilator and a BIPAP support pressure device]. Archivos de Bronconeumologia. 2003 Jan;39(1):13–8. PMID: 12550014. [Foreign language study].12550014
481 Laub M, Berg S, Midgren B, . Home mechanical ventilation in Sweden-inequalities within a homogenous health care system. Respiratory Medicine. 2004 Jan;98(1):38–42. PMID: 14959812. [Irrelevant comparison or no comparison].14959812
482 Laub M, Berg S, Midgren B. Symptoms, clinical and physiological findings motivating home mechanical ventilation in patients with neuromuscular diseases. Journal of Rehabilitation Medicine. 2006 July;38(4):250–4. PMID: 43977087. [Irrelevant intervention (or time frame)].16801208
483 Laub M, Midgren B. Survival of patients on home mechanical ventilation: a nationwide prospective study. Respiratory Medicine. 2007 Jun;101(6):1074–8. PMID: 17118638. [Irrelevant patient (age, medical condition)].17118638
484 Laub M, Midgren B. The effects of nocturnal home mechanical ventilation on daytime blood gas disturbances. Clinical Physiology & Functional Imaging. 2006 Mar;26(2):79–82. PMID: 16494596. [Irrelevant study design].16494596
485 Lavernhe S, Antoine J-C, Court-Fortune I, . Home care organization impacts patient management and survival in ALS. Amyotrophic Lateral sclerosis & Frontotemporal Degeneration. 2017 Jun 06:1–7. PMID: 2858547228585472. [Irrelevant setting/location].
486 Lechtzin N, Scott Y, Busse AM, . Early use of non-invasive ventilation prolongs survival in subjects with ALS. Amyotrophic Lateral Sclerosise. 2007 Jun;8(3):185–8. PMID: 17538782. [Outcomes not reported per device intervention].17538782
487 Lee S, Lee H, Eun LY, . Cardiac function associated with home ventilator care in Duchenne muscular dystrophy. Korean Journal of Pediatrics. 2018 Feb;61(2):59–63. PMID: 29563946. [Irrelevant outcome].29563946
488 Lee SK, Kim D-H, Choi WA, . The Significance of Transcutaneous Continuous Overnight CO(2) Monitoring in Determining Initial Mechanical Ventilator Application for Patients with Neuromuscular Disease. Annals of Rehabilitation Medicine. 2012 Feb;36(1):126–32. PMID: 22506245. [Irrelevant comparison or no comparison].22506245
489 Leger P, Robert D, Langevin B, . Chest wall deformities due to idiopathic kyphoscoliosis or sequelae of tuberculosis. European Respiratory Review. 1992;2(10):362–8. PMID: 23046343. [Published before 1995].23046343
490 Lehmann Y, Ewers M. Pathways of Invasive Ventilated Patients Released into Intensive Home Care: The Perspective of Home Care Providers. Gesundheitswesen. 2016. [Foreign language study].
491 Leon Valles M, Servia Goixart L, Prados Chica JJ, . Noninvasive mechanical ventilation. Fundamentals and application. [Spanish]. Medicina Paliativa. 2010;17(1):51–7. PMID: 366330238. [Foreign language study].
492 Li W, Li Z, Wu Q, . Early treatment with noninvasive positive pressure ventilation prolongs survival in amyotrophic lateral sclerosis patients. Amyotrophic Lateral Sclerosis. 2011 November;12:62. PMID: 70595728. [Abstract/conference proceeding].
493 Lien TC, Wang JH, Huang SH, . Comparison of bilevel positive airway pressure and volume ventilation via nasal or facial masks in patients with severe, stable COPD. Chung Hua i Hsueh Tsa Chih - Chinese Medical Journal. 2000 Jul;63(7):542–51. PMID: 10934807. [Irrelevant intervention (or time frame)].10934807
494 Lima V, Reinaux C, Alcoforado L, . Effectiveness of the use of heliox on nebulizer associated with noninvasive ventilation in chronic obstructive pulmonary disease patients: A randomized controlled trial. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923976. [Abstract/conference proceeding].
495 Lin CC. Comparison between nocturnal nasal positive pressure ventilation combined with oxygen therapy and oxygen monotherapy in patients with severe COPD. American Journal of Respiratory & Critical Care Medicine. 1996 Aug;154(2 Pt 1):353–8. PMID: 8756806. [Irrelevant study design].8756806
496 Lin MC, Huang CC, Lan RS, . Home mechanical ventilation: investigation of 34 cases in Taiwan. Changgeng Yi Xue Za Zhi. 1996 Mar;19(1):42–9. PMID: 8935374. [Abstract/conference proceeding].8935374
497 Lindenberger E, Wharton M, Bixby K, . Caring for the patient with ALS: It takes a village. Journal of Pain and Symptom Management. 2010 February;39 (2):373. PMID: 70088003. [Irrelevant study design].
498 Liu XL, Tan JY, Wang T, . Effectiveness of home-based pulmonary rehabilitation for patients with chronic obstructive pulmonary disease: A meta-analysis of randomized controlled trials. Rehabilitation Nursing. 2014;39(1):36–59. PMID: 52643422. [Irrelevant patient (age, medical condition)].23780865
499 Liu Y, Dai B, Su J, . [Effect of home noninvasive positive pressure ventilation on patients with severe stable chronic obstructive pulmonary disease: a meta-analysis]. Chung-Hua Chieh Ho Ho Hu Hsi Tsa Chih Chinese Journal of Tuberculosis & Respiratory Diseases. 2017 May 12;40(5):354–62. PMID: 28482421. [Foreign language study].28482421
500 Liu Y-J, Zhao J, Tang H. Non-invasive ventilation in acute respiratory failure: a meta-analysis. Clinical Medicine. 2016 Dec;16(6):514–23. PMID: 27927814. [Irrelevant patient (age, medical condition)].27927814
501 Liu YY, Chen YM, Liu JF, . Burdens of caregivers for patients with chronic ventilator-dependent: Impact of gender differences. Chest. Conference: CHEST. 2015;148(4 MEETING ABSTRACT). PMID: 72120487. [Abstract/conference proceeding].
502 Lofaso F, Brochard L, Hang T, . Home versus intensive care pressure support devices. Experimental and clinical comparison. American Journal of Respiratory & Critical Care Medicine. 1996 May;153(5):1591–9. PMID: 8630607. [Irrelevant patient (age, medical condition)].8630607
503 Lofaso F, Prigent H, Tiffreau V, . Long-term mechanical ventilation equipment for neuromuscular patients: meeting the expectations of patients and prescribers. Respiratory Care. 2014 Jan;59(1):97–106. PMID: 23764860. [Irrelevant comparison or no comparison].23764860
504 Lopes Almeida JP, Braga AC, Pinto A, . Respiratory predictors of ALS survival in home ventilated-compliant patients. Amyotrophic Lateral Sclerosis. 2012 October;13:186–7. PMID: 70920289. [Abstract/conference proceeding].
505 Lopes De Almeida JP, Cardoso Pinto A, Pinto S, . Cost-effectiveness of home telemonitoring non-invasive ventilation in ALS patients. Amyotrophic Lateral Sclerosis. 2009;10:186. PMID: 70078644. [Abstract/conference proceeding].
506 Lopes de Almeida JP, Pinto A, Pinto S, . Economic cost of home-telemonitoring care for BiPAP-assisted ALS individuals. Amyotrophic Lateral Sclerosis. 2012 Oct;13(6):533–7. PMID: 22873565. [Irrelevant study design].22873565
507 Lopez Martinez A, Carrillo Alcaraz A, Torres Serrato DO, . Analysis of a prediction scale for the failure of non-invasive ventilation in patiets with hypoxemic respiratory failure. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044485. [Abstract/conference proceeding].
508 Lopez-Campos JL, Failde I, Masa JF, . Factors related to quality of life in patients receiving home mechanical ventilation. Respiratory Medicine. 2008 Apr;102(4):605–12. PMID: 18068344. [Outcomes not reported per device intervention].18068344
509 Lopez-Campos JL, Failde I, Masa JF, . Transculturally adapted Spanish SRI questionnaire for home mechanically ventilated patients was viable, valid, and reliable. Journal of Clinical Epidemiology. 2008 Oct;61(10):1061–6. PMID: 18367377. [Irrelevant study design].18367377
510 Lorencio C, Sirvent JM. [Noninvasive ventilation: when, how and where?]. Medicina Intensiva. 2012 Dec;36(9):601–3. PMID: 23040612. [Foreign language study].23040612
511 Lorut C, Lefebvre A, Planquette B, . Early postoperative prophylactic noninvasive ventilation after major lung resection in COPD patients: a randomized controlled trial.[Erratum appears in Intensive Care Med. 2014 Mar;40(3):469 Note: Revel, Marie-Pierre [added]]. Intensive Care Medicine. 2014 Feb;40(2):220–7. PMID: 24292873. [Foreign language study].24292873
512 Lu P, Wu XM, Li ZG, . Clinical observation of home noninvasive positive pressure ventilation in hypercapnic patient with stable severe chronic obstructive pulmonary disease. [Chinese]. National Medical Journal of China. 2012 14 Feb;92(6):401–4. PMID: 365916957. [Foreign language study].22490901
513 Lujan M, Moreno A, Veigas C, . Non-invasive home mechanical ventilation: effectiveness and efficiency of an outpatient initiation protocol compared with the standard in-hospital model. Respiratory Medicine. 2007 Jun;101(6):1177–82. PMID: 17188485. [Outcomes not reported per device intervention].17188485
514 Luo H, Cheng P, Zhou R. [Sequential BiPAP following invasive mechanical ventilation in COPD patients with hypercapnic respiratory failure]. Bulletin of Hunan Medical University. 2001 Dec 28;26(6):563–5. PMID: 12536544. [Foreign language study].12536544
515 Luzzani A, Paissan M, Gasperini M, . [Home artificial ventilation-follow-up of 10 patients]. Minerva Anestesiologica. 1990 Oct;56(10):1275–80. PMID: 2290564. [Published before 1995].2290564
516 Lv Y, Lv Q, Lv Q, . Pulmonary infection control window as a switching point for sequential ventilation in the treatment of COPD patients: a meta-analysis. International Journal of Copd. 2017;12:1255–67. PMID: 28490869. [Irrelevant patient (age, medical condition)].28490869
517 Lyager S, Steffensen B, Juhl B. Indicators of need for mechanical ventilation in Duchenne muscular dystrophy and spinal muscular atrophy. Chest. 1995 Sep;108(3):779–85. PMID: 7656633. [Irrelevant comparison or no comparison].7656633
518 Lynch CA, O’Sullivan O, Santana-Vaz N, . Home mechanical ventilation (HMV): An expanding service in acute hospitals. Thorax. 2013 December;68:A154–A5. PMID: 71367341. [Abstract/conference proceeding].
519 Maastricht University Medical Center MMC, Erasmus Medical Center TNAF, Stichting Astma Bestrijding TN, . (Cost-)Effectiveness Interdisciplinary Community-Based COPD Management Program (INTERCOM). 2002 January. PMID: NCT00840892. [Irrelevant intervention (or time frame)].
520 Madden BP, Kariyawasam H, Siddiqi AJ, . Noninvasive ventilation in cystic fibrosis patients with acute or chronic respiratory failure. European Respiratory Journal. 2002;19(2):310–3. PMID: 34162833. [Irrelevant patient (age, medical condition)].11866011
521 Maggie Lit PK, Lee KH, Chow PS, . Home tele-monitoring can enhance patient care with home mechanical ventilation (HMV). Respirology. 2015 December;20:117. PMID: 72116194. [Abstract/conference proceeding].
522 Mahidol U. Randomized Cross-over TRD and CPAP for OSA. 2016 January. PMID: NCT02788487. [Irrelevant patient (age, medical condition)].
523 Make B, Gilmartin M, Brody JS, . Rehabilitation of ventilator-dependent subjects with lung diseases. The concept and initial experience. Chest. 1984 Sep;86(3):358–65. PMID: 6467996. [Published before 1995].6467996
524 Mandal S, Suh ES, Ramsay M, . Effect of heated humidification during initiation of home mechanical ventilation (HMV): A randomised cross-over trial. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841409. [Abstract/conference proceeding].
525 Mannino DM, Homa DM, Akinbami LJ, . Chronic obstructive pulmonary disease surveillance-United States, 1971-2000. Respiratory care. 2002;47(10):1184–99. [Irrelevant study design].12354338
526 Mansell S, Cutts S, Hackney I, . Impacts of ventilator data download on managing patients receiving home non-invasive ventilation (NIV). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614777280. [Abstract/conference proceeding].
527 Mansell SK, Cutts S, Hackney I, . Using domiciliary non-invasive ventilator data downloads to inform clinical decision-making to optimise ventilation delivery and patient compliance. BMJ open respiratory research. 2018;5(1):e000238. PMID: 29531743. [Irrelevant comparison or no comparison].29531743
528 Mansell SK, Cutts S, Kanakaraj R, . An outreach service for domiciliary noninvasive ventilation (NIV) improves access for patients. Thorax. 2017 December;72 (Supplement 3):A27. PMID: 619739048. [Abstract/conference proceeding].
529 Marchese S, Lo Coco D, Lo Coco A. Outcome and attitudes toward home tracheostomy ventilation of consecutive patients: a 10-year experience. Respiratory Medicine. 2008 Mar;102(3):430–6. PMID: 18023334. [Irrelevant intervention (or time frame)].18023334
530 Marinou K, Bovio G, Cena H, . Non-invasive ventilation influences resting energy expenditure in patients with amyotrophic lateral sclerosis. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2014 November;15:101. PMID: 71691020. [Abstract/conference proceeding].
531 Markovic N, Povitz M, Smith J, . Patterns of Non-Invasive Ventilation in Amyotrophic Lateral Sclerosis. Canadian Journal of Neurological Sciences. 2018 Jun 06:1–6. PMID: 2987170429871704. [Irrelevant comparison or no comparison].
532 Markstrom A, Sundell K, Lysdahl M, . Quality-of-life evaluation of patients with neuromuscular and skeletal diseases treated with noninvasive and invasive home mechanical ventilation. Chest. 2002 Nov;122(5):1695–700. PMID: 12426273. [Unclear device].12426273
533 Marotta A, Borel JC, Galerneau LM, . Incident cardiovascular events in severely obese patients treated with continuous positive airway pressure (CPAP)/non invasive ventilation (NIV): A 5.5 years follow-up. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2015;191(no pagination). PMID: 72049026. [Abstract/conference proceeding].
534 Marquez-Martin E, Cejudo P, Lopez-Campos JL, . Home mechanical ventilation and respiratory rehabilitation: Influence in bode index, quality of live and inflammatory parameters. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2012;185(no pagination). PMID: 71990457. [Abstract/conference proceeding].
535 Marsden PA, Green H, McNamara A, . Long-term domiciliary non-invasive ventilation in COPD in a UK hospital. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2012;185(no pagination). PMID: 71987695. [Abstract/conference proceeding].
536 Marti S, Pallero M, Ferrer J, . Predictors of mortality in chest wall disease treated with noninvasive home mechanical ventilation. Respiratory Medicine. 2010 Dec;104(12):1843–9. PMID: 20869225. [Irrelevant study design].20869225
537 Martin TJ, Hovis JD, Costantino JP, . A randomized, prospective evaluation of noninvasive ventilation for acute respiratory failure. American Journal of Respiratory & Critical Care Medicine. 2000 Mar;161(3 Pt 1):807–13. PMID: 10712326. [Irrelevant setting/location].10712326
538 Masa J, J F. [Home mechanical ventilation: the current outlook]. Archivos de Bronconeumologia. 1994 Jan;30(1):29–39. PMID: 8149072. [Foreign language study].8149072
539 Masa JF, Celli BR, Riesco JA, . Noninvasive positive pressure ventilation and not oxygen may prevent overt ventilatory failure in patients with chest wall diseases. Chest. 1997;112(1):207–13. PMID: 27343620. [Irrelevant intervention (or time frame)].9228378
540 Mascardi V, Grecchi B, Barlascini C, . Effectiveness of temporary positive expiratory pressure (T-PEP) at home and at hospital in patients with severe chronic obstructive pulmonary disease. Journal of Thoracic Disease. 2016;8(10):2895–902. PMID: 613270989. [Unclear device].27867566
541 Masefield S, Vitacca M, Ambrosino N. The unmet needs of home mechanical ventilator users in Europe: The patients’ perspective. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614779803. [Abstract/conference proceeding].
542 Masefield S, Vitacca M, Dreher M, . Attitudes and preferences of home mechanical ventilation users from four European countries: An ERS/ELF survey. ERS Monograph. 2017 01 Apr;3 (2) (no pagination)(00015-2017). PMID: 617366889. [Irrelevant study design].
543 Mason M, Chadwick R, Smith I. Use of home noninvasive ventilation (NIV) in patients with ankylosing spondylitis (AS). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2012;40(no pagination). PMID: 71923974. [Abstract/conference proceeding].
544 Mastinu A, Stobbione T. Home mechanical ventilation: Indications, critical and practical experience. Chest. Conference: CHEST. 2015;148(4 MEETING ABSTRACT). PMID: 72132871. [Abstract/conference proceeding].
545 Matsumura T, Saito T, Fujimura H, . [A longitudinal cause-of-death analysis of patients with Duchenne muscular dystrophy]. Rinsho Shinkeigaku - Clinical Neurology. 2011 Oct;51(10):743–50. PMID: 22019865. [Foreign language study].22019865
546 Matsumura T, Saito T, Miyai I, . [A pilot study to establish a support system using SpO2 monitoring system and videoconference system for patients under home mechanical ventilation]. Rinsho Shinkeigaku - Clinical Neurology. 2000 Jul;40(7):683–8. PMID: 11186905. [Foreign language study].11186905
547 Matsushita K, Ishikawa T, Sumita S, . Adaptive Servo-Ventilation Therapy Is the Most Effective Therapy for the Sleep Disorderd Breathing in Patients for Cardiac Resynchronization Therapy Candidates. Journal of arrhythmia. 2011;27(4):203. [Abstract/conference proceeding].
548 Mayo C, Minnesota H. Home-based Health Management of Chronic Obstructive Lung Disease (COPD) Patients. 2016 September. PMID: NCT02999685. [Irrelevant intervention (or time frame)].
549 McCrory DC, Brown C, Sarah E, . Management of acute exacerbations of COPD: A summary and appraisal of published evidence. Chest. 2001;119(4):1190–209. PMID: 32679450. [Irrelevant setting/location].11296189
550 McCurdy BR. Noninvasive positive pressure ventilation for acute respiratory failure patients with chronic obstructive pulmonary disease (COPD): an evidence-based analysis. Ontario Health Technology Assessment Series. 2012;12(8):1–102. PMID: 23074436. [Irrelevant setting/location].23074436
551 McDowell G, MacFarlane D, Tourish R, . Early experience with 2-way remote monitoring for the initiation of volume assured home non-invasive ventilation. Thorax. 2017 December;72 (Supplement 3):A150. PMID: 619738733. [Abstract/conference proceeding].
552 McKim DA, Griller N, LeBlanc C, . Twenty-four hour noninvasive ventilation in Duchenne muscular dystrophy: a safe alternative to tracheostomy. Can Respir J. 2013 Jan-Feb;20(1):e5–9. PMID: 23457679. [Irrelevant study design].23457679
553 McKim DA, Griller N, LeBlanc C, . Twenty-four hour noninvasive ventilation in Duchenne muscular dystrophy: a safe alternative to tracheostomy. Canadian respiratory journal. 2013;20(1):e5–e9. [Irrelevant study design].23457679
554 Meddeb K, Ayachi J, Ennouri E, . Compared NIV use and outcomes in Acute Exacerbations of Chronic Obstructive Pulmonary Disease (AECOPD) vs acute exacerbations of restrictive diseases. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044714. [Abstract/conference proceeding].
555 Meddeb K, Ayachi J, Ennouri E, . Non invasive ventilation use in Severe Hypercapnic Encephalopathy. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044508. [Abstract/conference proceeding].
556 Meecham Jones DJ, Paul EA, Jones PW, . Nasal pressure support ventilation plus oxygen compared with oxygen therapy alone in hypercapnic COPD. American Journal of Respiratory & Critical Care Medicine. 1995 Aug;152(2):538–44. PMID: 7633704. [Irrelevant study design].7633704
557 Meinesz AF, Bladder G, Goorhuis JF, . [18 years experience with mechanical ventilation in patients with Duchenne muscular dystrophy]. Nederlands Tijdschrift voor Geneeskunde. 2007 Aug 18;151(33):1830–3. PMID: 17874640. [Foreign language study].17874640
558 Menadue C, Alison JA, Piper AJ, . Non-invasive ventilation during arm exercise and ground walking in patients with chronic hypercapnic respiratory failure. Respirology. 2009 Mar;14(2):251–9. PMID: 19210652. [Irrelevant intervention (or time frame)].19210652
559 Metchedjin A, Rabec C, Georges M, . Non-invasive ventilation in neuromuscular diseases. A 15-year retrospective study. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71840829. [Abstract/conference proceeding].
560 Meurice JC, Cornette A, Philip-Joet F, . Evaluation of autoCPAP devices in home treatment of sleep apnea/hypopnea syndrome. Sleep Medicine. 2007 Nov;8(7-8):695–703. PMID: 17638595. [Irrelevant patient (age, medical condition)].17638595
561 Michailidis V, Steiropoulos P, Perantoni E, . Validation of the Greek version of the severe respiratory insufficiency questionnaire. Journal of Thoracic Disease. Conference: 21st Panhellenic Congress of Thoracic Disease. Greece. 2012;4(no pagination). PMID: 614571883614571883. [Abstract/conference proceeding].
562 Michigan State U, National Cancer I, Spectrum Health H, . The Symptom Experience Study in Persons With Non-Small Cell Lung Cancer. 2013 January. PMID: NCT01786187. [Irrelevant patient (age, medical condition)].
563 Midgren B, Olofson J, Harlid R, . Home mechanical ventilation in Sweden, with reference to Danish experiences. Swedish Society of Chest Medicine. Respiratory Medicine. 2000 Feb;94(2):135–8. PMID: 10714418. [Irrelevant study design].10714418
564 Midgren B, Schedin U, Olofson J. [Artificial respiration at home seen in a 5-year perspective. Established treatment, but remarkable differences among the counties]. Lakartidningen. 2000 Nov 22;97(47):5483–4, 7–90. PMID: 11192774. [Foreign language study].11192774
565 Mifsud Bonnici D, Sanctuary T, Creagh-Brown B, . Observational cohort study of outcome of patients referred to a regional weaning centre. Thorax. 2013 December;68:A68–A9. PMID: 71367156. [Abstract/conference proceeding].
566 Mifsud Bonnici D, Sanctuary T, Warren A, . Prospective observational cohort study of patients with weaning failure admitted to a specialist weaning, rehabilitation and home mechanical ventilation centre. BMJ Open. 2016 Mar 08;6(3):e010025. PMID: 26956162. [Irrelevant comparison or no comparison].26956162
567 Mishima M, Kawakami K, Hirai T, . Respiratory impedance during positive expiratory airway pressure in patients with chronic obstructive pulmonary disease. Frontiers of Medical & Biological Engineering. 1999;9(1):63–73. PMID: 10354910. [Irrelevant intervention (or time frame)].10354910
568 Miyamoto K, Aoi K, Kawakami Y. [Effect of home oxygen therapy on prognosis of patients with chronic pulmonary disease associated with pulmonary hypertension]. Nihon Kyobu Shikkan Gakkai Zasshi Japanese Journal of Thoracic Diseases. 1992 Dec;30 Suppl:175–9. PMID: 1306222. [Published before 1995].1306222
569 Moga AM, e Marchie M, Saey D, . Bi-level Positive Airway Pressure (BiPAP) with standard exhalation valve does not improve maximum exercise capacity in patients with COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. 2015 Feb;12(1):46–54. PMID: 24946024. [Irrelevant intervention (or time frame)].24946024
570 Mohd Slim MA. Use of non-invasive ventilation (NIV) in acute type 2 respiratory failure (T2RF) in patients with COPD at a tertiary hospital in new zealand. Respirology. 2017 November;22 (Supplement 3):184–5. PMID: 619967573. [Abstract/conference proceeding].
571 Moizuddin M, Vujnic S, Janssen W, . Preliminary report on the impact of continuous positive airway pressure (CPAP) therapy on health-related quality of life in patients with obstructive sleep apnea and chronic obstructive pulmonary disease (overlap syndrome). Sleep. 2010;33:A166. PMID: 70244212. [Abstract/conference proceeding].
572 Momomura S-I, Seino Y, Kihara Y, . Adaptive servo-ventilation therapy using an innovative ventilator for patients with chronic heart failure: a real-world, multicenter, retrospective, observational study (SAVIOR-R). Heart & Vessels. 2015 Nov;30(6):805–17. PMID: 25103691. [Irrelevant patient (age, medical condition)].25103691
573 Mokhlesi B, Tulaimat A, Evans AT, . Impact of adherence with positive airway pressure therapy on hypercapnia in obstructive sleep apnea. Journal of Clinical Sleep Medicine. 2006;2(01):57–62. [Irrelevant outcome].17557438
574 Moran F, Bradley JM, Piper AJ. Non-invasive ventilation for cystic fibrosis. Cochrane Database of Systematic Reviews. 2009(1). [Abstract/conference proceeding].
575 Moreira J, Freitas C, Pinto T, . Efficacy assessement of home mechanical ventilation: Comparison of ventilator software data with home respiratory poligraphy (pilot study). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841424. [Abstract/conference proceeding].
576 Moss AH, Oppenheimer EA, Casey P, . Patients with amyotrophic lateral sclerosis receiving long-term mechanical ventilation. Advance care planning and outcomes. Chest. 1996 Jul;110(1):249–55. PMID: 8681635. [Irrelevant study design].8681635
577 Mu P-F, Wang K-WK, Chen Y-C, . A systematic review of the experiences of adult ventilator-dependent patients. JBI Library of Systematic Reviewis. 2010;8(8):344–81. PMID: 27820005. [Irrelevant patient (age, medical condition)].27820005
578 Muir JF, Girault C, Cardinaud JP, . Survival and long-term follow-up of tracheostomized patients with COPD treated by home mechanical ventilation. A multicenter French study in 259 patients. French Cooperative Study Group. Chest. 1994 Jul;106(1):201–9. PMID: 8020273. [Published before 1995].8020273
579 Muller-Pawlowski H, von Moers A, Raffenberg M, . [BiPAP therapy of respiratory disorders in patients with congenital neuromuscular diseases]. Medizinische Klinik. 1995 Apr;90(1 Suppl 1):35–8. PMID: 7616916. [Foreign language study].7616916
580 Murphy P, Arbane G, Bisquera A, . S38 Home mechanical ventilation (hmv) and home oxygen therapy (hot) following an acute exacerbation of copd in patients with persistent hypercapnia: predicting 1 year admission-free survival in the hot-hmv uk trial. BMJ Publishing Group Ltd; 2017. [Abstract/conference proceeding].
581 Murphy P, Arbane G, Bourke S, . Improving admission free survival with home mechanical ventilation (HMV) and home oxygen therapy (HOT) following life threatening COPD exacerbations: HoT-HMV UK Trial NCT00990132. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614779787. [Abstract/conference proceeding].
582 Murphy P, Arbane G, Bourke S, . S115 Hot-hmv uk trial secondary outcome analysis: early readmission is reduced by the addition of home mechanical ventilation to home oxygen therapy in copd patients with chronic respiratory failure following a life-threatening exacerbation. BMJ Publishing Group Ltd; 2016. [Abstract/conference proceeding].
583 Murphy P, Brignall K, Williams A, . Health-related quality of life in obesity hypoventilation syndrome (OHS) prior to initiation of home mechanical ventilation (HMV). Thorax. 2009 December;64:A137. PMID: 70254684. [Abstract/conference proceeding].
584 Murphy P, Hart N. Who benefits from home mechanical ventilation? Clinical Medicine, Journal of the Royal College of Physicians of London. 2009;9(2):160–3. PMID: 355133963. [Irrelevant study design].
585 Murphy P, Moxham J, Polkey M, . HOT HMV UK: An investigation into mechanisms of action of home mechanical ventilation (HMV) following acute hypercapnic exacerbations of COPD. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2011;38(no pagination). PMID: 72116497. [Abstract/conference proceeding].
586 Murphy P, Moxham J, Polkey M, . S119 UK HOT-HMV Trial: Acceptability and tolerability of high pressure domiciliary non-invasive ventilation (NIV) in COPD. Thorax. 2011;66:(Suppl 4):A55–A. [Abstract/conference proceeding].
587 Murphy P, Polkey MI, Hart N. Hot HMV UK: Sleep disruption following initiation of domiciliary NIV in hypercapnic COPD. Thorax. 2010 December;65:A145. PMID: 70326016. [Abstract/conference proceeding].
588 Murphy PB, Arbane G, Bisquera A, . Home mechanical ventilation (HMV) and home oxygen therapy (HOT) following an acute exacerbation of COPD in patients with persistent hypercapnia: Predicting 1 year admission-free survival in the hot-HMV UK trial. Thorax. 2017 December;72 (Supplement 3):A26–A7. PMID: 619739045. [Abstract/conference proceeding].
589 Murphy PB, Arbane G, Bourke S, . Hot-HMV UK trial secondary outcome analysis: early readmission is reduced by the addition of home mechanical ventilation to home oxygen therapy in COPD patients with chronic respiratory failure following a lifethreatening exacerbation. Thorax. 2016 December;71:A68–A9. PMID: 615030762. [Abstract/conference proceeding].
590 Murphy PB, Arbane G, Phillips R, . Home mechanical ventilation (HMV) and home oxygen therapy (HOT) following an acute exacerbation of COPD in patients with persistent hypercapnia: Results of the per protocol analysis from the hot-HMV UK trial. Thorax. 2017 December;72 (Supplement 3):A25–A6. PMID: 619739041. [Abstract/conference proceeding].
591 Murphy PB, Moxham J, Polkey MI, . UK hot-HMV trial: Acceptability and tolerability of high pressure domiciliary non-invasive ventilation (NIV) in COPD. Thorax. 2011 December;66:A55. PMID: 70627758. [Abstract/conference proceeding].
592 Musil J, Hirsch V, Vondra V, . The significance of early noninvasive ventilation support in patients with severe exacerbation of chronic obstructive lung disease (COLD). [Czech]. Studia Pneumologica et Phtiseologica. 1998;58(6):264–6. PMID: 29117653. [Foreign language study].29117653
593 Naeck R, Bounoiare D, Portmann A, . Modifications of sleep quality and cardiac variability during initiation of domiciliary noninvasive ventilation in patients with chronic respiratory failure. Fundamental and Clinical Pharmacology. 2012 April;26:59. PMID: 70866644. [Abstract/conference proceeding].
594 Naeck R, Portmann A, Freitas U, . Polysomnographic changes during initiation of domiciliary noninvasive ventilation in patients with chronic respiratory failure. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2012;185(no pagination). PMID: 71987712. [Abstract/conference proceeding].
595 Naestved Hospital UHR, Hvidovre University Hospital AU, Bispebjerg Hospital T, . Breathing Exercises in Asthma Targeting Dysfunctional Breathing. 2017 April 27. PMID: NCT03127059. [Irrelevant patient (age, medical condition)].
596 Nakamura Y, Saito Y, Kubota N, . Identification of sleep hypoventilation in young individuals with Becker muscular dystrophy: A pilot study. Brain and Development. 2018. PMID: 20005192162000519216. [Irrelevant comparison or no comparison].
597 Narayanaswami P, Bertorini TE, Pourmand R, . Long-term tracheostomy ventilation in neuromuscular diseases: patient acceptance and quality of life. Neurorehabilitation & Neural Repair. 2000;14(2):135–9. PMID: 15470824. [Irrelevant intervention (or time frame)].15470824
598 Nardi J, Leroux K, Orlikowski D, . Home monitoring of daytime mouthpiece ventilation effectiveness in patients with neuromuscular disease. Chronic Respiratory Disease. 2016 01 Feb;13(1):67–74. PMID: 608233371. [Irrelevant comparison or no comparison].26703922
599 Nardi J, Prigent H, Adala A, . Nocturnal oximetry and transcutaneous carbon dioxide in home-ventilated neuromuscular patients. Respiratory Care. 2012 Sep;57(9):1425–30. PMID: 22348449. [Irrelevant intervention (or time frame)].22348449
600 Nasilowski J, Szkulmowski Z, Migdal M, . [Prevalence of home mechanical ventilation in Poland]. Pneumonologia i Alergologia Polska. 2010;78(6):392–8. PMID: 21077031. [Irrelevant outcome].21077031
601 Nasilowski J, Wachulski M, Trznadel W, . The evolution of home mechanical ventilation in poland between 2000 and 2010. Respiratory Care. 2015 Apr;60(4):577–85. PMID: 25492950. [Irrelevant comparison or no comparison].25492950
602 National Guideline C. British Thoracic Society guidelines for home oxygen use in adults. 2015.[Duplicate Study].
603 National Guideline C. Care of dying adults in the last days of life. 2015. [Irrelevant patient (age, medical condition)].
604 National Guideline C. Care of the hospitalized patient with acute exacerbation of COPD. 2016. [Irrelevant patient (age, medical condition)].
605 National Guideline C. Chronic pain disorder medical treatment guideline. 2017. [Irrelevant patient (age, medical condition)].
606 National Guideline C. Diagnosis and treatment of respiratory illness in children and adults. 2013. [Irrelevant patient (age, medical condition)].
607 National Guideline C. Humidification during invasive and noninvasive mechanical ventilation: 2012. 2012. [Irrelevant patient (age, medical condition)].
608 National Guideline C. Idiopathic pulmonary fibrosis. The diagnosis and management of suspected idiopathic pulmonary fibrosis. 2013. [Irrelevant intervention (or time frame)].
609 National Guideline C. Metastatic spinal cord compression. Diagnosis and management of adults at risk of and with metastatic spinal cord compression. 2008. [Irrelevant patient (age, medical condition)].
610 National Guideline C. Multiple sclerosis: management of multiple sclerosis in primary and secondary care. 2014. [Irrelevant patient (age, medical condition)].
611 National Guideline C. Palliative care for adults. 2013. [Irrelevant patient (age, medical condition)].
612 National Guideline C. Tuberculosis. 2016. [Irrelevant patient (age, medical condition)].
613 Negele C, Genger H, Eichmeier J. [Objective measurement of work of breathing with CPAP and BiLEVEL ventilation]. Biomedizinische Technik. 1997;42 Suppl:301–4. PMID: 9517161. [Foreign language study].9517161
614 Nelisen V, Metzing S, Schnepp W. [Experiences of Patients with Invasive and Non-Invasive Home Mechanical Ventilation - a Systematic Review of Qualitative Research]. Pneumologie. 2017 Oct 18;18:18. PMID: 29046009. [Foreign language study].29046009
615 Nestler C, Simon P, Petroff D, . Individualized positive end-expiratory pressure in obese patients during general anaesthesia: A randomized controlled clinical trial using electrical impedance tomography. British Journal of Anaesthesia. 2017 01 Dec;119(6):1194–205. PMID: 620134380. [Irrelevant patient (age, medical condition)].29045567
616 Netchitailo M, Lavergne F, Bravard AS, . Ventilatory management in COPD-associated obstructive sleep apnea syndrome. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105973. [Abstract/conference proceeding].
617 Network for Engineering ER. Effect of a Pilot Group Hand-washing Program on Handwashing Behaviors Among Elementary School Children in Assam. 2015 November. PMID: NCT02617225. [Irrelevant patient (age, medical condition)].
618 Ng SWS, Tsang WY, Chan YYA, . Home non-invasive ventilation service for patients with chronic respiratory failure. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2011;38(no pagination). PMID: 72116602. [Abstract/conference proceeding].
619 Nicolini A, Barlascini C, Piroddi IMG, . Effectiveness and safety of mouthpiece ventilation and nocturnal non-invasive ventilation in patients with kyphoscoliosis: Short and long-term outcomes after an episode of acute respiratory failure. Revista Portuguesa de Pneumologia. 2016 Mar-Apr;22(2):75–81. PMID: 26748589. [Unclear device].26748589
620 Nicolini A, Grecchi B, Veronesi G, . Effectiveness of temporary positive expiratory pressure (T-PEP) at home and at hospital in patients with severe COPD. Chest. 2016 October;150 (4 Supplement 1):150A. PMID: 613468857. [Abstract/conference proceeding].
621 Nicolini A, Mascardi V, Grecchi B, . Comparison of effectiveness of temporary positive expiratory pressure versus oscillatory positive expiratory pressure in severe COPD patients. Clinical Respiratory Journal. 2018 March;12(3):1274–82. PMID: 621392317. [Irrelevant intervention (or time frame)].28665556
622 Nilius G, Katamadze N, Domanski U, . Non-invasive ventilation with intelligent volume-assured pressure support versus pressure-controlled ventilation: effects on the respiratory event rate and sleep quality in COPD with chronic hypercapnia. International Journal of Copd. 2017;12:1039–45. PMID: 28408814. [Irrelevant intervention (or time frame)].28408814
623 Nilius G, Katamadze N, Domanski U, . Non-invasive ventilation with intelligent volume-assured pressure support versus pressure-controlled ventilation: Effects on the respiratory event rate and sleep quality in COPD with chronic hypercapnia. International Journal of COPD. 2017;12:1039–45. [Irrelevant intervention (or time frame)].28408814
624 Non-invasive positive pressure ventilation for neuromuscular diseases. Practice guidelines. [French]. Revue des maladies respiratoires. 2006 Nov;23(5 Pt 4):14S5–S40. PMID: 45009282. [Foreign language study].
625 Nowbar S, Burkart KM, Gonzales R, . Obesity-associated hypoventilation in hospitalized patients: prevalence, effects, and outcome. Am J Med. 2004 Jan 1;116(1):1–7. PMID: 14706658. [Irrelevant patient (age, medical condition)].14706658
626 Nowbar S, Burkart KM, Gonzales R, . Obesity-associated hypoventilation in hospitalized patients: prevalence, effects, and outcome. The American journal of medicine. 2004;116(1):1–7. [Irrelevant patient (age, medical condition)].14706658
627 Nowinski A, Bielen P, Jonczak L, . [Influence of treatment with continuous positive airway pressure on respiratory muscle function and physical fitness in patients with obstructive sleep apnoea and overlap syndrome]. Pneumonologia i Alergologia Polska. 2007;75(1):46–56. PMID: 17541912. [Foreign language study].17541912
628 Nugent A-M, Smith IE, Shneerson JM. Domiciliary-assisted ventilation in patients with myotonic dystrophy. Chest. 2002 Feb;121(2):459–64. PMID: 11834657. [Irrelevant comparison or no comparison].11834657
629 Nuila M, Burman M, Selvaraj E, . Can body mass index (BMI) predict the likelihood of nocturnal non-invasive home mechanical ventilation (HMV) re-admission rate in chronic hypercapnic chronic obstructive pulmonary disease (CHCOPD)? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841396. [Abstract/conference proceeding].
630 Oda AL, Carvalho EV, Ferreira FB, . Importance of the criteria of indication and adequacy of ventilation of patients with motor neuron disease. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2017 November;18 (Supplement 2):288–9. PMID: 619350106. [Abstract/conference proceeding].29113490
631 Odense University Hospital T, CoLab Denmark RoSD, University of Southern Denmark DLA. Telemedical Training for Chronically Ill COPD Patients: a Cross Sectoral Study. 2016 August. PMID: NCT02754232. [Irrelevant patient (age, medical condition)].
632 O’Donohue WJ, Jr G, R. M G, . Long-term mechanical ventilation. Guidelines for management in the home and at alternate community sites. Report of the Ad Hoc Committee, Respiratory Care Section, American College of Chest Physicians. Chest. 1986 Jul;90:(1 Suppl):1S–37S. PMID: 3522124. [Published before 1995].3522124
633 Oga T, Taniguchi H, Kita H, . Analysis of the relationship between health status and mortality in hypercapnic patients with noninvasive ventilation. Clinical Respiratory Journal. 2017 November;11(6):772–80. PMID: 607513815. [Irrelevant comparison or no comparison].26605994
634 Oga T, Taniguchi H, Kita H, . Comparison of Different Disease-Specific Health-Related Quality of Life Measurements in Patients with Long-Term Noninvasive Ventilation. Canadian Respiratory Journal. 2017;2017:8295079. PMID: 28588383. [Irrelevant comparison or no comparison].28588383
635 Ogna A, Nardi J, Prigent H, . Prognostic Value of Initial Assessment of Residual Hypoventilation Using Nocturnal Capnography in Mechanically Ventilated Neuromuscular Patients: A 5-Year Follow-up Study. Frontiers in Medicine. 2016;3:40. PMID: 27679799. [Outcomes not reported per device intervention].27679799
636 Ogna A, Nardi J, Prigent H, . Prognostic value of residual hypoventilation in mechanically ventilated neuromuscular patients: A 5 years follow-up study. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105959. [Abstract/conference proceeding].
637 Ogna A, Prigent H, Falaize L, . Bench evaluation of commercially available and newly developed interfaces for mouthpiece ventilation. The clinical respiratory journal. 2016 Dec 27;27:27. PMID: 28026119. [Irrelevant study design].28026119
638 Ogna A, Prigent H, Falaize L, . Bench evaluation of commercially available and newly developed interfaces for mouthpiece ventilation. The clinical respiratory journal. 2018 Mar;12(3):890–4. PMID: 28026119. [Irrelevant study design].28026119
639 Ogna A, Prigent H, Quera Salva MA, . Prognostic value of nocturnal hypoventilation in unventilated neuromuscular disease patients. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780623. [Abstract/conference proceeding].
640 Ohi M, Kuno K. [Effectiveness of domiciliary noninvasive positive pressure ventilation in improving blood gas levels and the performance of daily activities. NIPPV Study Group]. Nihon Kokyuki Gakkai Zasshi. 2000 Mar;38(3):166–73. PMID: 10846396. [Foreign language study].10846396
641 Ojeda Castillejo E, e Lucas Ramos P, Lopez Martin S, . Noninvasive Mechanical Ventilation in Patients With Obesity Hypoventilation Syndrome. Long-term Outcome and Prognostic Factors. Archivos de Bronconeumologia. 2014;17. PMID: 53243547. [Foreign language study].
642 Ojeda Castillejo E, e Lucas Ramos P, Lopez Martin S, . Noninvasive mechanical ventilation in patients with obesity hypoventilation syndrome. Long-term outcome and prognostic factors. Archivos de Bronconeumologia. 2015 Feb;51(2):61–8. PMID: 24703500. [Duplicate].24703500
643 Olofson J, Dellborg C, Sullivan M, . Qualify of life and palliation predict survival in patients with chronic alveolar hypoventilation and nocturnal ventilatory support. Quality of Life Research. 2009 Apr;18(3):273–80. PMID: 19219411. [Irrelevant intervention (or time frame)].19219411
644 Orfanos S, Jaffuel D, Perrin C, . Switch of noninvasive ventilation (NIV) to continuous positive airway pressure (CPAP) in patients with obesity hypoventilation syndrome: a pilot study. BMC Pulmonary Medicine. 2017 Mar 14;17(1):50. PMID: 28288605. [Irrelevant comparison or no comparison].28288605
645 Orlikowski D, Prigent H, Ambrosi X, . Comparison of ventilator-integrated end-tidal CO<inf>2</inf> and transcutaneous CO<inf>2</inf> monitoring in home-ventilated neuromuscular patients. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780275. [Abstract/conference proceeding].
646 Orlikowski D, Prigent H, Ambrosi X, . Comparison of ventilator-integrated end-tidal CO2 and transcutaneous CO2 monitoring in home-ventilated neuromuscular patients. Respiratory Medicine. 2016 Aug;117:7–13. PMID: 27492508. [Irrelevant intervention (or time frame)].27492508
647 Orlikowski D, Prigent H, Lofaso F, . Comparison of ventilator-integrated end-tidal CO2 and transcutaneous CO2 monitoring in home-ventilated neuromuscular patients. Respiration. 2016;91 (5):439–40. PMID: 611888147. [Abstract/conference proceeding].
648 Ornek T, Erboy F, Atalay F, . Evaluation of clinical data and mortality among COPD patients receiving domiciliary NIMV therapy. Turk Toraks Dergisi. 2014 July;15(3):112–6. PMID: 373450270. [Irrelevant outcome].
649 Osadnik C, Stuart-Andrews C, Ellis S, . Positive expiratory pressure via mask does not improve ventilation inhomogeneity more than huffing and coughing in individuals with stable chronic obstructive pulmonary disease and chronic sputum expectoration. Respiration. 2014;87(1):38–44. PMID: 23752553. [Irrelevant intervention (or time frame)].23752553
650 Oscroft NS, Ali M, Gulati A, . A randomised crossover trial comparing volume assured and pressure preset noninvasive ventilation in stable hypercapnic COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. 2010 Dec;7(6):398–403. PMID: 21166627. [Irrelevant study design].21166627
651 Oscroft NS, Quinnell TG, Shneerson JM, . A prospective, randomised, single-blind, crossover study comparing standard bi-level with volume assured non-invasive positive pressure ventilation in chronic obstructive pulmonary disease patients with chronic ventilatory failure [Abstract S78]. Thorax. 2008;63(Suppl VII):A36. PMID: CN-00676874 UPDATE. [Abstract/conference proceeding].
652 Ouanes-Besbes L, Abdallah SB, Ouanes I, . Effects of home ventilation on survival: Comparison in obstructive and restrictive diseases. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841402. [Abstract/conference proceeding].
653 Oxford University Hospitals NHST. Factors Associated With Chronic Respiratory Failure in Obesity. 2011 June. PMID: NCT01380418. [Irrelevant intervention (or time frame)].
654 Pahnke J, Bullemer F, Heindl S, . [Patient-related rejection of nasal IPPV therapy. Patients, reasons, follow-up]. Medizinische Klinik. 1997 Apr 28;92 Suppl 1:73–4. PMID: 9235480. [Foreign language study].9235480
655 Paleiron N, Andre M, Grassin F, . Evaluation of preoperative non-invasive ventilation in thoracic surgery for lung cancer: The preOVNI study GFPC 12-01. [French]. Revue des maladies respiratoires. 2013;30(3):231–7. PMID: CN-00906620 UPDATE. [Foreign language study].23497934
656 Pallero M, Puy C, Guell R, . Ambulatory adaptation to noninvasive ventilation in restrictive pulmonary disease: a randomized trial with cost assessment. Respiratory Medicine. 2014 Jul;108(7):1014–22. PMID: 24837977. [Irrelevant intervention (or time frame)].24837977
657 Palm A, Midgren B, Janson C, . Gender differences in patients starting long-term home mechanical ventilation due to obesity hypoventilation syndrome. Respiratory Medicine. 2016 01 Jan;110:73–8. PMID: 607250714. [Irrelevant intervention (or time frame)].26680503
658 Palmer JM, Ward NR, Robinson JC, . A large retrospective evaluation of domiciliary and outpatient initiation of home mechanical ventilation. Thorax. 2014 December;69:A206. PMID: 71689065. [Abstract/conference proceeding].
659 Panariello J, Corriger E. Mechanical ventilation of patients with Duchenne muscular dystrophy. [French]. Cahiers de Kinesitherapie. 1990(142):47–53. PMID: 2021106120211061. [Foreign language study].
660 Panchabhai T, Pioro E, Aboussouan L, . Course of decline of lung function based on tolerance to noninvasive ventilation in patients with amyotrophic lateral sclerosis. Chest. 2016;1):A533. PMID: 72268387. [Abstract/conference proceeding].
661 Pande A, Singhal P, Kumar R, . Effect of home-based pulmonary rehabilitation programme on disability in patients with chronic obstructive pulmonary disease. The Indian journal of chest diseases & allied sciences. 2005 2005;47(3):217–9. PMID: 41107138. [Irrelevant intervention (or time frame)].16022153
662 Pankow W, Becker H, Kohler U, . [Patient-ventilator interaction during noninvasive pressure supported spontaneous respiration in patients with hypercapnic COPD]. Pneumologie. 2001 Jan;55(1):7–12. PMID: 11236359. [Foreign language study].11236359
663 Pankow W, Hijjeh N, Schulder F, . Influence of noninvasive ventilation on the work of breathing in obesity. [German]. Medizinische Klinik. 1997 28 Apr;92(SUPPL. 1):54–60. PMID: 27225941. [Foreign language study].9235477
664 Pankow W, Hijjeh N, Schuttler F, . Influence of noninvasive positive pressure ventilation on inspiratory muscle activity in obese subjects. European Respiratory Journal. 1997 Dec;10(12):2847–52. PMID: 9493672. [Irrelevant patient (age, medical condition)].9493672
665 Park D, Lee GJ, Kim HY, . Different characteristics of ventilator application between tracheostomy- and noninvasive positive pressure ventilation patients with amyotrophic lateral sclerosis. Medicine. 2017 Mar;96(10):e6251. PMID: 28272226. [Irrelevant intervention (or time frame)].28272226
666 Parker J, Robinson GV, McGown AD, . Predictors of successful domiciliary non-invasive ventilation for motor neurone disease in a district eneral hospital. Thorax. 2009 December;64:A75. PMID: 70254542. [Abstract/conference proceeding].
667 Parreira VF, Delguste P, Jounieaux V, . Effectiveness of controlled and spontaneous modes in nasal two-level positive pressure ventilation in awake and asleep normal subjects. Chest. 1997 Nov 5;112(5):1267–77. PMID: 9367467. [Irrelevant intervention (or time frame)].9367467
668 Parreira VF, Delguste P, Jounieaux V, . Effectiveness of controlled and spontaneous modes in nasal two-level positive pressure ventilation in awake and asleep normal subjects. Chest. 1997;112(5):1267–77. [Irrelevant intervention (or time frame)].9367467
669 Parreira VF, Jounieaux V, Delguste P, . Determinants of effective ventilation during nasal intermittent positive pressure ventilation. European Respiratory Journal. 1997 September;10(9):1975–82. PMID: 27406427. [Irrelevant intervention (or time frame)].9311488
670 Pasquina P, Adler D, Farr P, . What does built-in software of home ventilators tell us? An observational study of 150 patients on home ventilation. Respiration. 2012;83(4):293–9. PMID: 21952176. [Irrelevant outcome].21952176
671 Pasquina P, Bourqui P, Farr P, . [Follow-up of patients with home mechanical ventilation: experience in Geneva, Switzerland]. Revue Medicale Suisse. 2008 Nov 19;4(180):2518–20, 22–4. PMID: 19127896. [Foreign language study].19127896
672 Pasquina P, Farr P, Bourqui P, . Home-based versus hospital-based monitoring of long-term home ventilation: A pilot study. Respiration. 2011 June;82 (1):91. PMID: 70494343. [Abstract/conference proceeding].
673 Patout M, Arbane G, Owusu-Afriyie J, . Home non-invasive ventilation (NIV): Patients cognitive performance and skills at setup. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780359. [Abstract/conference proceeding].
674 Patout M, Ramsay M, Mackie M, . Home mechanical ventilation (HMV): Setup and outcome in Europe. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105958. [Abstract/conference proceeding].
675 Patrick Murphy Gs, St Thomas’ Charity RI, ResMed RF, . Home Mechanical Ventilation vs Home Oxygen Therapy in COPD. 2009 October. PMID: NCT00990132. [Completed Clinical Trial].
676 Pehrsson K, Nachemson A, Olofson J, . Respiratory failure in scoliosis and other thoracic deformities: A survey of patients with home oxygen or ventilator therapy in Sweden. Spine. 1992;17(6):714–8. PMID: 22222384. [Published before 1995].1626306
677 Pehrsson K, Olofson J, Larsson S, . Quality of life of patients treated by home mechanical ventilation due to restrictive ventilatory disorders. Respiratory Medicine. 1994 Jan;88(1):21–6. PMID: 8029509. [Published before 1995].8029509
678 Pepin JL, Borel JC, Janssens JP. Obesity hypoventilation syndrome: an underdiagnosed and undertreated condition. Am J Respir Crit Care Med. 2012 Dec 15;186(12):1205–7. doi: 10.1164/rccm.201210-1922ED. PMID: 23250497. [Irrelevant study design].23250497
679 Pépin J-L, Borel J-C, Janssens J-P. Obesity hypoventilation syndrome: an underdiagnosed and undertreated condition. Am Thoracic Soc; 2012. [Irrelevant study design].
680 Perez-Bautista O, Venegas AR, Uncal MV, . Non invasive positive pressure ventilation for reducing exacerbation in very severe chronic obstructive pulmonary disease (COPD). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614777404. [Abstract/conference proceeding].
681 Perrin C, El Far Y, Vandenbos F, . Domiciliary nasal intermittent positive pressure ventilation in severe COPD: effects on lung function and quality of life. European Respiratory Journal. 1997 Dec;10(12):2835–9. PMID: 9493670. [Irrelevant comparison or no comparison].9493670
682 Perrin C, Vandenbos F, Tamisier R, . [Impact of acute respiratory failure on survival of COPD patients managed with long-term non-invasive ventilation and oxygen therapy]. Revue des Maladies Respiratoires. 2000 Feb;17(1):91–7. PMID: 10756560. [Foreign language study].10756560
683 Perrin C, Wolter P, Berthier F, . [Comparison of volume preset and pressure preset ventilators during daytime nasal ventilation in chronic respiratory failure]. Revue des Maladies Respiratoires. 2001 Feb;18(1):41–8. PMID: 14639176. [Foreign language study].14639176
684 Perrone A, Quacquarelli ME, Barbarossa A, . [Possible effects of non invasive mechanical ventilation on respiratory drive and muscles]. Clinica Terapeutica. 2007 Jan-Feb;158(1):11–6. PMID: 17405654. [Foreign language study].17405654
685 Perruchoud A, Tschan M, Kopp C, . [Rehabilitation program with IPPB-home treatment in severe chronic obstructive lung disease: hospitalizations and cost analysis]. Schweizerische Medizinische Wochenschrift Journal Suisse de Medecine. 1980 Feb 09;110(6):229–31. PMID: 6990485. [Published before 1995].6990485
686 Perruchoud A. [Introduction and guidelines for oxygen home therapy and for home respirators]. Schweizerische Rundschau fur Medizin Praxis. 1982 Feb 23;71(8):337–42. PMID: 6951158. [Published before 1995].6951158
687 Peter JV, Moran JL, Phillips-Hughes J, . Noninvasive ventilation in acute respiratory failure-a meta-analysis update. Critical Care Medicine. 2002 Mar;30(3):555–62. PMID: 11990914. [Irrelevant patient (age, medical condition)].11990914
688 Philippe G, Mickael C, Olivier C, . With the same O2 flow, FiO2 decreases during non-invasive ventilation (NIV) with a home ventilator (HV) versus nasal normobaric long-term oxygen therapy (LTOT). Annals of Intensive Care. Conference: French Intensive Care Society, International Congress Reanimation. 2018;8(1 Supplement 1). PMID: 620836844. [Abstract/conference proceeding].
689 Philips R. Positive Pressure Treatment of Obstructive Sleep Apnea. 2008 January. PMID: NCT00636181. [Irrelevant patient (age, medical condition)].
690 Piesiak P, Brzecka A, Kosacka M, . Efficacy of noninvasive volume targeted ventilation in patients with chronic respiratory failure due to kyphoscoliosis. Advances in Experimental Medicine & Biology. 2015;838:53–8. PMID: 25315620. [Irrelevant comparison or no comparison].25315620
691 Pinto A, e Carvalho M, Evangelista T, . Nocturnal pulse oximetry: a new approach to establish the appropriate time for non-invasive ventilation in ALS patients. Amyotrophic Lateral Sclerosis & Other Motor Neuron Disorders. 2003 Apr;4(1):31–5. PMID: 12745616. [Irrelevant comparison or no comparison].12745616
692 Piper AJ, Sullivan CE. Effects of long-term nocturnal nasal ventilation on spontaneous breathing during sleep in neuromuscular and chest wall disorders. European Respiratory Journal. 1996;9(7):1515–22. PMID: 26233799. [Irrelevant study design].8836668
693 Piper AJ, Wang D, Yee BJ, . Randomised trial of CPAP vs bilevel support in the initial management of patients with obesity hypoventilation syndrome. Sleep and Biological Rhythms. 2006;4:(Suppl 1):A11. PMID: CN-01092029 NEW. [Abstract/conference proceeding].
694 Piquilloud L, Paratte G, Verhoeven J, . Comparison of trigger delay, pressurization capacity and patient-ventilator synchrony during non-invasive ventilation delivered by old and new generation turbine based ICU and home ventilators. Intensive Care Medicine. 2013 October;39:S360. PMID: 71446458. [Abstract/conference proceeding].
695 Piraino T. 2016 Year in Review: Noninvasive Ventilation. Respiratory Care. 2017 May;62(5):623–8. PMID: 28442588. [Irrelevant study design].28442588
696 Planes C, D’Ortho M-P, Foucher A, . Efficacy and cost of home-initiated auton-CPAP versus conventional nCPAP. Sleep. 2003 Mar 15;26(2):156–60. PMID: 12683473. [Irrelevant patient (age, medical condition)].12683473
697 Plummer AL, O’Donohue WJ, Jr P. Consensus conference on problems in home mechanical ventilation. American Review of Respiratory Disease. 1989 Aug;140(2):555–60. PMID: 2669582. [Published before 1995].2669582
698 Polkey MI, Hawkins P, Kyroussis D, . Inspiratory pressure support prolongs exercise induced lactataemia in severe COPD. Thorax. 2000 Jul;55(7):547–9. PMID: 10856312. [Irrelevant comparison or no comparison].10856312
699 Poon CA, Becker KA, Littner MR. Noninvasive positive airway pressure in hypercapnic respiratory failure in noncardiac medical disorders. Sleep Medicine Clinics. 2010 September;5(3):451–70. PMID: 359535316. [Irrelevant patient (age, medical condition)].
700 Porta R, Ambrosino N. Noninvasive positive pressure ventilation in COPD patients with chronic respiratory insufficiency. Monaldi Archives for Chest Disease. 2000;55(6):509–10. PMID: 32162188. [Irrelevant study design].11272642
701 Porta R, Vitacca M, Clini E, . Physiological effects of posture on mask ventilation in awake stable chronic hypercapnic COPD patients. European Respiratory Journal. 1999 Sep;14(3):517–22. PMID: 10543269. [Irrelevant intervention (or time frame)].10543269
702 Povitz M, Rose L, Shariff SZ, . Home Mechanical Ventilation: A 12-Year Population-Based Retrospective Cohort Study. Respiratory Care. 2018 Apr;63(4):380–7. PMID: 29208755. [Irrelevant intervention (or time frame)].29208755
703 Prasad SA, Tannenbaum EL, Mikelsons C. Physiotherapy in cystic fibrosis. Journal of the Royal Society of Medicine. 2000;93: Suppl 38:27–36. PMID: 10911816. [Irrelevant study design].10911816
704 Prinianakis G, Delmastro M, Carlucci A, . Effect of varying the pressurisation rate during noninvasive pressure support ventilation. European Respiratory Journal. 2004 Feb;23(2):314–20. PMID: 14979510. [Irrelevant setting/location].14979510
705 Qiao H, Li WY, Hou TH, . Influence of continuous positive airway pressure treatment on the hemorheology of patients with chronic obstructive pulmonary disease and sleep apnea syndrome. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2005 21 May;9(19):64–5. PMID: 41575804. [Foreign language study].
706 Qu Y, Peng H, Chen P, . [Combination of chest physiotherapy and intermittent non-invasive mechanical ventilation for chronic obstructive pulmonary disease patients with respiratory failure]. Zhong Nan da Xue Xue Bao Yi Xue Ban = Journal of Central South University Medical Sciences. 2009 Jul;34(7):655–8. PMID: 19648681. [Foreign language study].19648681
707 Quinnell TG, Pilsworth S, Shneerson JM, . Prolonged invasive ventilation following acute ventilatory failure in COPD: weaning results, survival, and the role of noninvasive ventilation. Chest. 2006 Jan;129(1):133–9. PMID: 16424423. [Irrelevant patient (age, medical condition)].16424423
708 Quint M, Walker E, Adeniji K, . Acute use of built in software of non invasive ventilators-A case series. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71843471. [Abstract/conference proceeding].
709 Raaphorst J, Tuijp J, Verweij L, . Respiratory impairment in patients with motor neuron disease: Referral process and first assessment at a home ventilation service in the Netherlands. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2013 November;14:90. PMID: 71717006. [Abstract/conference proceeding].
710 Raaphorst J, Tuijp J, Verweij L, . Treatment of respiratory impairment in patients with motor neuron disease in the Netherlands: patient preference and timing of referral. European Journal of Neurology. 2013 Dec;20(12):1524–30. PMID: 23398243. [Irrelevant intervention (or time frame)].23398243
711 Rabec C, Cuvelier A, Cheval C, . [Noninvasive ventilation. The 2015 guidelines from the Groupe Assistance Ventilatoire (GAV) of the Societe de Pneumologie de Langue Francaise (SPLF)]. Revue des Maladies Respiratoires. 2016 Dec;33(10):905–10. PMID: 27567439. [Foreign language study].27567439
712 Rabkin J, Ogino M, Goetz R, . Japanese and American ALS patient preferences regarding TIV (tracheostomy with invasive ventilation): A cross-national survey. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2014 June;15(3-4):185–91. PMID: 373186520. [Irrelevant study design].24720451
713 Rabkin JG, Albert SM, Tider T, . Predictors and course of elective long-term mechanical ventilation: A prospective study of ALS patients. Amyotrophic Lateral Sclerosise. 2006 Jun;7(2):86–95. PMID: 16753972. [Irrelevant intervention (or time frame)].16753972
714 Raffenberg M, Geerdes-Fenge H, Muller-Pawlowski H, . Invasive and non-invasive home ventilation - Changes between 1982 and 1996. [German]. Medizinische Klinik. 1999 15 Apr;94(SPEC. ISS. 1):18–21. PMID: 29197437. [Abstract/conference proceeding].29197437
715 Raffenberg M, Muller-Pawlowski H, Geerdes-Fenge H, . Indications, methods and results of intermittent positive pressure ventilation at home. [German]. Atemwegs- und Lungenkrankheiten. 1997;23(3):138–41. PMID: 27196123. [Foreign language study].27196123
716 Raffenberg M. Noninvasive positive pressure ventilation in chronic respiratory insufficiency. [German]. Deutsche Medizinische Wochenschrift. 2000 25 Feb;125(8):224. PMID: 30130855. [Foreign language study].10755854
717 Rafiq MK. Non-invasive ventilation (NIV) in patients with Amyotrophic Lateral Sclerosis (ALS). Physiotherapy (United Kingdom). 2013;99(1):92. PMID: CN-00912216 UPDATE. [Abstract/conference proceeding].
718 Ragab FA, Ahmad GH, Andraos AW, . Conventional vs non invasive ventilation in acute respiratory failure. Australian Journal of Basic and Applied Sciences. 2009;3(3):2232–42. [Irrelevant setting/location].
719 Rahal L, Garrido AG, Cruz RJ. [Non-invasive ventilation: when to use?]. Revista Da Associacao Medica Brasileira. 2005 Sep-Oct;51(5):245–6. PMID: 16270133. [Foreign language study].16270133
720 Rajhan A, Whitfield S, Mustfa N, . Non invasive ventilation-our experience with clinic and home initiation. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2015;191(no pagination). PMID: 72050614. [Abstract/conference proceeding].
721 Ramsay M, Mandal S, Suh E-S, . Parasternal electromyography to determine the relationship between patient-ventilator asynchrony and nocturnal gas exchange during home mechanical ventilation set-up. Thorax. 2015 Oct;70(10):946–52. PMID: 26197816. [Irrelevant intervention (or time frame)].26197816
722 Randerath WJ, Kamps N, Brambring J, . [Recommendations for invasive home mechanical ventilation]. Pneumologie. 2011 Feb;65(2):72–88. PMID: 21294061. [Foreign language study].21294061
723 Raphael JC, Chevret S, Auriant I, . [Long-term ventilation at home in adults with neurological diseases]. Revue des Maladies Respiratoires. 1998 Sep;15(4):495–505. PMID: 9805760. [Foreign language study].9805760
724 Raphael JC, Chevret S, Chastang C, . A prospective multicentre study of home mechanical ventilation in Duchenne de Boulogne muscular dystrophy. European Respiratory Review. 1992;2(10):312–6. PMID: 23046332. [Published before 1995].23046332
725 Raphael JC, Chevret S, Chastang C, . Randomised trial of preventive nasal ventilation in Duchenne muscular dystrophy. French Multicentre Cooperative Group on Home Mechanical Ventilation Assistance in Duchenne de Boulogne Muscular Dystrophy. Lancet. 1994 Jun 25;343(8913):1600–4. PMID: 7911921. [Published before 1995].7911921
726 Raphael JC, Dazord A, Jaillard P, . Assessment of quality of life for home ventilated patients with Duchenne muscular dystrophy. [French]. Revue Neurologique. 2002;158(4):453–60. PMID: 34475151. [Foreign language study].11984488
727 Raphael JC. [Home mechanical ventilation in Duchenne de Boulogne muscular dystrophy. Mandatory ventilation and preventive ventilation]. Revue des Maladies Respiratoires. 1987;4(5):195–7. PMID: 3324229. [Foreign language study].3324229
728 Rappard S, Hickey J. Just the Berries. Use of CPAP and BiPAP in acute respiratory failure. Canadian family physician Medecin de famille canadien. 2001 Feb;47:269–70. PMID: 33446412. [Irrelevant patient (age, medical condition)].11228026
729 Raschke F, Fischer J. [Comparison of CPAP and BiPAP equipment with reference to work of breathing, pressure and flow constancy]. Pneumologie. 1995 Mar;49: Suppl 1:205–8. PMID: 7617616. [Foreign language study].7617616
730 Recommendations of HAS: Practical issues in home non-invasive ventilation in patients with neuromuscular disease. [French]. Revue des maladies respiratoires. 2006 Sep;23:(4 Suppl):13S153–5. PMID: 45013272. [Foreign language study].17057641
731 ResMed CRITCRIG. Registry of Stable Hypercapnic Chronic Obstructive Pulmonary Disease Treated With Non-Invasive Ventilation. 2016 July. PMID: NCT02811588. [Completed Clinical Trial].
732 ResMed RB. Autotitrating Versus Standard Non-invasive Ventilation (NIV) in Newly Diagnosed Patients. 2009 April. PMID: NCT00901485. [Completed Clinical Trial].
733 Respiratory Home Care Focus G. AARC clinical practice guideline. Long-term invasive mechanical ventilation in the home-2007 revision & update. [Reprint of Respir Care. 1995 Dec;40(12):1313-20; PMID: 10153257]. Respiratory Care. 2007 Aug;52(8):1056–62. PMID: 17715560. [Irrelevant intervention (or time frame)].17715560
734 Restrick LJ, Fox NC, Braid G, . Comparison of nasal pressure support ventilation with nasal intermittent positive pressure ventilation in patients with nocturnal hypoventilation. European Respiratory Journal. 1993 Mar;6(3):364–70. PMID: 8472827. [Published before 1995].8472827
735 Reuveny R, Ben-Dov I, Gaides M, . Ventilatory support during training improves training benefit in severe chronic airway obstruction. Israel Medical Association Journal. 2005 March;7(3):151–5. PMID: 40424957. [Irrelevant intervention (or time frame)].15792258
736 Reybet-Degas O, Lacroix S, Gonzales G, . Survival after acute respiratory decompensation of chronic respiratory failure. Role of long term oxygen therapy and mechanical ventilation at home. [French]. Semaine des Hopitaux. 1989;65(42):2551–6. PMID: 19277183. [Published before 1995].19277183
737 Richards S, Saman H, Packer M, . Compliance with non invasive home ventilation (NIHV) and its impact on survival: A retrospective descriptive study. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849050. [Abstract/conference proceeding].
738 Richards S, Saman H, Packer M, . Non invasive home ventilation (NIHV) in chronic obstructive pulmonary disease (COPD): Impact on hospital admission rates and length of stay. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849039. [Abstract/conference proceeding].
739 Riessen R, Schwabbauer N, Berg B, . Nasal high-flow oxygen in patients with hypoxic respiratory failure: Effect on functional and subjective respiratory parameters compared to conventional oxygen therapy and noninvasive ventilation. Critical Care. 2012 20 Mar;16:S49. PMID: 70735076. [Abstract/conference proceeding].
740 Rigault JY, Leroy F, Poncey C, . [Prolonged mechanical nasal ventilation. Apropos of 27 case of myopathy]. Revue des Maladies Respiratoires. 1991;8(5):479–85. PMID: 1767120. [Published before 1995].1767120
741 Ritchie A, Douglas J, Bell S. A review of domiciliary non invasive ventilation (NIV) in adult cystic fibrosis in a tertiary referral centre. Sleep and Biological Rhythms. 2013 October;11:48–9. PMID: 71226688. [Abstract/conference proceeding].
742 Rittayamai N, Phuangchoei P, Praphruetkit N, . High-flow nasal oxygen cannula in patients with chronic obstructive pulmonary disease requiring ventilator support. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044456. [Abstract/conference proceeding].
743 Rizzi M, Grassi M, Pecis M, . A specific home care program improves the survival of patients with chronic obstructive pulmonary disease receiving long term oxygen therapy. Archives of Physical Medicine & Rehabilitation. 2009 Mar;90(3):395–401. PMID: 19254602. [Irrelevant intervention (or time frame)].19254602
744 Robart P, Make BJ, McInturff SL, . Long-term invasive mechanical ventilation in the home. Respiratory Care. 1995;40(12):1313–20. PMID: 25363579. [Foreign language study].10153257
745 Robert D, Gerard M, Leger P, . [Permanent mechanical ventilation at home via a tracheotomy in chronic respiratory insufficiency]. Revue Francaise des Maladies Respiratoires. 1983;11(6):923–36. PMID: 6669800. [Published before 1995].6669800
746 Robert D. Home mechanical ventilation. [French]. Itbm-Rbm. 2005 January;26(1):24–7. PMID: 40093573. [Foreign language study].
747 Rochwerg B, Brochard L, Elliott MW, . Official ERS/ATS clinical practice guidelines: Noninvasive ventilation for acute respiratory failure. European Respiratory Journal. 2017;50(4). [Irrelevant patient (age, medical condition)].
748 Rodrigues MK, Oliveira MF, Soares A, . Additive effects of non-invasive ventilation to hyperoxia on cerebral oxygenation in COPD patients with exercise-related O2 desaturation. Clinical Physiology & Functional Imaging. 2013 Jul;33(4):274–81. PMID: 23692616. [Irrelevant intervention (or time frame)].23692616
749 Rodrigues S, Ramalho R, Vilas-Boas F, . Percutaneous endoscopic gastrostomy placement in patients with amyotrophic lateral sclerosis with noninvasive ventilation. American Journal of Gastroenterology. 2012 October;107:S771. PMID: 70895516. [Abstract/conference proceeding].
750 Rodriguez Hortal M, Hedborg A, Nygren-Bonnier M, . Incremental test with noninvasive ventilation (NIV) support vs oxygen supplementation in adult patients with cystic fibrosis. Pediatric Pulmonology. 2016 October;51:375. PMID: 612358533. [Abstract/conference proceeding].
751 Roland M, Restrick L, Mills P, . Effect of regular intermittent noninvasive positive pressure ventilation in stable hypercapnic chronic obstructive pulmonary disease patients. Thorax. 1999;54(SUPPL. 3). [Abstract/conference proceeding].
752 Romero C, Sanchez J, Almadana V, . Results of noninvasive ventilation in obese patients with acute respiratory failure. Chest. Conference: CHEST World Congress. 2014;145(3 MEETING ABSTRACT). PMID: 71429104. [Abstract/conference proceeding].
753 Rose L, McKim DA, Katz SL, . Home mechanical ventilation in Canada: A national survey. Respiratory Care. 2015 01 May;60(5):695–704. PMID: 606573441. [Irrelevant patient (age, medical condition)].25587173
754 Rosen CL, Auckley D, Benca R, . A multisite randomized trial of portable sleep studies and positive airway pressure autotitration versus laboratory-based polysomnography for the diagnosis and treatment of obstructive sleep apnea: the HomePAP study. Sleep. 2012 Jun 01;35(6):757–67. PMID: 22654195. [Irrelevant patient (age, medical condition)].22654195
755 Rossi A, Polese G. Ventilatory strategy from intensive care unit to home. European Respiratory Review. 2000;10(74):354–7. [Irrelevant study design].
756 Russo V, Di Meo F, Rago A, . Impact of Continuous Positive Airway Pressure Therapy on Atrial Electromechanical Delay in Obesity-Hypoventilation Syndrome Patients. Journal of Cardiovascular Electrophysiology. 2016 Mar;27(3):327–34. PMID: 26552735. [Irrelevant study design].26552735
757 Rutgers M, Lucassen H, Kesteren RV, . Respiratory insufficiency and ventilatory support. 39th ENMC International Workshop, Naarden, The Netherlands, 26-28 January 1996. European Consortium on Chronic Respiratory Insufficiency. Neuromuscular Disorders. 1996 Dec;6(6):431–5. PMID: 9027851. [Irrelevant study design].9027851
758 Rutgers TSUoNJ, National Heart L. RCT of Effects of Device-guided Breathing on Ambulatory BP. 2008 May. PMID: NCT01184755. [Irrelevant patient (age, medical condition)].
759 Sadigov A. Long-term noninvasive ventilation in COPD associated with non-cystic fibrosis bronchiectasis: Is high-intensity NIV the right way to go? Chest. 2016 October;150 (4 Supplement 1):881A. PMID: 613468864. [Foreign language study].
760 Sady CCR, Freitas US, Portmann A, . Automatic sleep staging from ventilator signals in non-invasive ventilation. Computers in Biology and Medicine. 2013 01 Aug;43(7):833–9. PMID: 369104654. [Irrelevant patient (age, medical condition)].23746724
761 Saeed El Hoshy M, Ahmed Eshmawey H, Sayed El Tawab S. Outcome of pulmonary rehabilitation in patients with COPD: Comparison between patients receiving exercise training and those receiving exercise training and CPAP. Egyptian Journal of Chest Diseases and Tuberculosis. 2017 October;66(4):609–16. PMID: 618796402. [Irrelevant intervention (or time frame)].
762 Sahetya S, Allgood S, Gay PC, . Long-Term Mechanical Ventilation. Clinics in Chest Medicine. 2016 01 Dec;37(4):753–63. PMID: 612774378. [Irrelevant study design].27842754
763 Saito T. [Mechanical ventilation for amyotrophic lateral sclerosis-Making a comparison between hospital and home care]. Rinsho Shinkeigaku - Clinical Neurology. 1999 Jan;39(1):70–1. PMID: 10377809. [Foreign language study].10377809
764 Saito T. Mechanical ventilation for amyotropic lateral sclerosis making a comparison between hospital and home care. [Japanese]. Clinical Neurology. 1999;39(1):70–1. PMID: 29254556. [Foreign language study].10377809
765 Sakamoto T, Kuratomi A, Ishizaki M, . Investigation on the introduction status of noninvasive positive pressure ventilation in patients with amyotrophic lateral sclerosis. Journal of the Neurological Sciences. 2017 October;381 (Supplement 1):710. PMID: 620184770. [Abstract/conference proceeding].
766 Salahuddin N, Haider K, Husain SJ, . Outcome of home mechanical ventilation. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan. 2005 Jul;15(7):387–90. PMID: 16197864. [Irrelevant intervention (or time frame)].16197864
767 Salamand J, Robert D, Gerard M. The cost of chronic respiratory disease before and after decision for mechanical ventilation at home. Lyon Medical. 1981;245(8):559–62. [Published before 1995].
768 Salord N, Mayos M, Fortuna AM, . Effect of continuous positive airway pressure therapy on metabolic control in patients with morbid obesity and obstructive sleep apnoea. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841998. [Abstract/conference proceeding].
769 Salord N, Mayos M, Miralda RM, . Continuous positive airway pressure in clinically stable patients with mild-to-moderate obesity hypoventilation syndrome and obstructive sleep apnoea. Respirology. 2013 Oct;18(7):1135–42. PMID: 23714281. [Outcomes not reported per device intervention].23714281
770 Samanta R, Dixit A, Harris S, . Lung protective mechanical ventilation for acute respiratory failure is not being implemented in UK clinical practice. Thorax. 2017 December;72 (Supplement 3):A81–A2. PMID: 619739046. [Abstract/conference proceeding].
771 Sampol G, Sagales MT, Roca A, . Nasal continuous positive airway pressure with supplemental oxygen in coexistent sleep apnoea-hypopnoea syndrome and severe chronic obstructive pulmonary disease. European Respiratory Journal. 1996 Jan;9(1):111–6. PMID: 8834343. [Irrelevant intervention (or time frame)].8834343
772 Sanchez Agudo L, Cornudella R, Estopa Miro R, . [Guidelines for indications and use of domiciliary continuous oxygen (DCO) therapy. SEPAR guidelines]. Archivos de Bronconeumologia. 1998 Feb;34(2):87–94. PMID: 9557179. [Foreign language study].9557179
773 Sanchez Quiroga M, Mogollon Jimenez M, Gomez De Terreros F, . Echocardiographic changes with positive airway pressure in obesity hypoventilation syndrome. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2017;195(no pagination). PMID: 617713228. [Abstract/conference proceeding].
774 Sancho J, Servera E, Diaz JL, . Home tracheotomy mechanical ventilation in patients with amyotrophic lateral sclerosis: causes, complications and 1-year survival. Thorax. 2011 Nov;66(11):948–52. PMID: 21693569. [Irrelevant study design].21693569
775 Sanjak M, Bravver EK, Bockenek W, . C-reactive protein (CRP) is significantly higher in amyotrophic lateral sclerosis (ALS) patients on non-invasive ventilation (NIV) and tracheostomy-invasive ventilation (TIV) compared with als patients at intake clinic evaluation and decreases following riluzole administration-is crp potentially a biomarker for treatment responsiveness? Neurology. Conference: 70th Annual Meeting of the American Academy of Neurology, AAN. 2018;90(15 Supplement 1). PMID: 622309793. [Abstract/conference proceeding].
776 Santos Bouza A, De La Torre Garcia R, Robelo Pardo M, . Home discharge from the intensive care unit in patients with permanent mechanical ventilatory support. [Spanish]. Medicina Intensiva. 1998 April;22(4):143–7. PMID: 28258550. [Foreign language study].28258550
777 Sawicka EH, Loh L, Branthwaite MA. Domiciliary ventilatory support: an analysis of outcome. Thorax. 1988 Jan;43(1):31–5. PMID: 3127911. [Published before 1995].3127911
778 Scaffardi A, Mandal S, Ramsay M, . The effect of a structured technical training session on patient adherence to domiciliary non-invasive ventilation: A pre-post intervention study. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841343. [Abstract/conference proceeding].
779 Scala R. [Home mechanical ventilation in chronic obstructive pulmonary disease]. Clinica Terapeutica. 2006 Mar-Apr;157(2):159–64. PMID: 16817506. [Foreign language study].16817506
780 Scales DC. The Implications of a Tracheostomy for Discharge Destination. Am J Respir Crit Care Med. 2015 Aug 15;192(4):404–5. doi: 10.1164/rccm.201505-1007ED. PMID: 26278790. [Irrelevant intervention (or time frame)].26278790
781 Scales DC. The implications of a tracheostomy for discharge destination. Am Thoracic Soc; 2015. [Irrelevant intervention (or time frame)].
782 Scarpazza P, Incorvaia C, Amboni P, . Long-term survival in elderly patients with a do-not-intubate order treated with noninvasive mechanical ventilation. International Journal of Copd. 2011;6:253–7. PMID: 21814461. [Irrelevant patient (age, medical condition)].21814461
783 Schaefer IL, Dorschner S. [“Quality of life means acting independently”. How do COPD-patients experience non-invasive ventilation? A qualitative study]. Pflege. 2005 Jun;18(3):159–68. PMID: 15997713. [Foreign language study].15997713
784 Schafer H, Ewig S, Hasper E, . Failure of CPAP therapy in obstructive sleep apnoea syndrome: predictive factors and treatment with bilevel-positive airway pressure. Respir Med. 1998 Feb;92(2):208–15. PMID: 9616514. [Irrelevant patient (age, medical condition)].9616514
785 Schäfer H, Ewig S, Hasper E, . Failure of CPAP therapy in obstructive sleep apnoea syndrome: predictive factors and treatment with bilevel-positive airway pressure. Respiratory medicine. 1998;92(2):208–15. [Irrelevant patient (age, medical condition)].9616514
786 Schellhas V, Glatz C, Beecken I, . Upper airway obstruction induced by non-invasive ventilation using an oronasal interface. Sleep and Breathing. 2018 17 Feb:1–8. PMID: 620740848620740848. [Irrelevant comparison or no comparison].
787 Schenk P, Eber E, Funk GC, . Non-invasive and invasive out of hospital ventilation in chronic respiratory failure: Consensus report of the working group on ventilation and intensive care medicine of the Austrian Society of Pneumology. [German]. Wiener Klinische Wochenschrift. 2016 01 Feb;128:1–36. PMID: 608669139. [Foreign language study].26802031
788 Schettino GPP, Reis MAS, Galas F, . [Mechanical ventilation noninvasive with positive pressure]. Jornal Brasileiro De Pneumologia: Publicacao Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia. 2007;33 Suppl 2S:S92–105. PMID: 18026667. [Foreign language study].18026667
789 Schonhofer B, Rosenbluh J, Voshaar T, . [Ergometry separates sleep apnea syndrome from obesity-hypoventilation after therapy positive pressure ventilation therapy]. Pneumologie. 1997 Dec;51(12):1115–9. PMID: 9487773. [Foreign language study].9487773
790 Schonhofer B. [Mechanical Ventilation - Essentials of 4 German Guidelines]. Deutsche Medizinische Wochenschrift. 2018 06;143(11):793–6. PMID: 29807378. [Foreign language study].29807378
791 Schonhofer B. [Noninvasive positive pressure ventilation in acute respiratory insufficiency-a report of the International Consensus Conference in Internal Medicine, Paris 13-14 April 2000]. Pneumologie. 2001 Jan;55(1):21–30. PMID: 11236353. [Foreign language study].11236353
792 Schucher B, Hein H, Kirsten D, . [Use of home mechanical ventilation in patients with high grade chronic obstructive lung disease (COPD)]. Pneumologie. 1999 Oct;53: Suppl 2:S103–6. PMID: 10613056. [Foreign language study].10613056
793 Schucher B, Hein H, Magnussen H. [Acceptance and long-term results of home mechanical ventilation in various thoracic diseases]. Medizinische Klinik. 1999 Apr;94(1 Spec No):22–6. PMID: 10373730. [Foreign language study].10373730
794 Schucher B, Magnussen H. [Mechanical ventilation in chronic ventilatory insufficiency]. Pneumologie. 2007 Oct;61(10):644–52. PMID: 17620231. [Foreign language study].17620231
795 Schulz MR, Wiebel M, Schulz V. [Intermittent self-ventilation in neuromuscular diseases. Comparison of lung function parameters in ventilated and non-ventilated patients]. Medizinische Klinik. 1996 Apr 12;91 Suppl 2:42–4. PMID: 8684324. [Foreign language study].8684324
796 Schwarz SB, Callegari J, Hamm C, . Is Outpatient Control of Long-Term Non-Invasive Ventilation Feasible in Chronic Obstructive Pulmonary Disease Patients? Respiration. 2018;95(3):154–60. PMID: 29232680. [Irrelevant comparison or no comparison].29232680
797 Schwarz SB, Magnet FS, Schonhofer B, . Home mechanical Ventilation - Concepts and Therapy Recommendations. [German]. Deutsche medizinische Wochenschrift (1946). 2017 01 Aug;142(16):1197–204. PMID: 618034243. [Foreign language study].28810276
798 Scott A, Cahill T, Langan D, . Patient’s attitudes, beliefs and satisfaction with domiciliary non-invasive ventilation (NIV). Irish Journal of Medical Science. 2014 November;1):S499–S500. PMID: 71730764. [Abstract/conference proceeding].
799 Sellares J, Ferrer M, Anton A, . Discontinuing noninvasive ventilation in severe chronic obstructive pulmonary disease exacerbations: A randomised controlled trial. European Respiratory Journal. 2017;50(1). [Irrelevant intervention (or time frame)].
800 Selva A, Sanchez L, Munoz X, . Respiratory failure due to muscle weakness in inflammatory myopathis: Maintenance therapy with home mechanical ventilation is lifesaving. Acta Myologica. 1999;3:73. PMID: 29362924. [Abstract/conference proceeding].29362924
801 Sevick MA, Kamlet MS, Hoffman LA, . Economic cost of home-based care for ventilator-assisted individuals: a preliminary report. Chest. 1996 Jun;109(6):1597–606. PMID: 8769517. [Irrelevant study design].8769517
802 Sevick MA, Sereika S, Matthews JT, . Home-based ventilator-dependent patients: measurement of the emotional aspects of home caregiving. Heart & Lung. 1994 Jul-Aug;23(4):269–78. PMID: 7960852. [Published before 1995].7960852
803 Shang J, Ma C, Poghosyan L, . The prevalence of infections and patient risk factors in home health care: A systematic review. American Journal of Infection Control. 2014 May;42(5):479–84. PMID: 53062019. [Irrelevant patient (age, medical condition)].24656786
804 Shelly A, Prabhu N, Jirange P, . Quality of life improves with individualized home-based exercises in critical care survivors. Indian Journal of Critical Care Medicine. 2017;21(2):89–93. [Irrelevant intervention (or time frame)].28250604
805 Shetty S, Fernandes A, Patel S, . Unanticipated Nocturnal Oxygen Requirement during Positive Pressure Therapy for Sleep Apnea and Medical Comorbidities. Journal of Clinical Sleep Medicine. 2017 Jan 15;13(1):73–9. PMID: 27655454. [Irrelevant comparison or no comparison].27655454
806 Shneerson JM, Smith IE. Long term survival after hospital discharge from a Progressive Care Programme (PCP) for patients failing to wean from invasive ventilation on ICU. Thorax. 1997;52(SUPPL. 6). [Abstract/conference proceeding].
807 Shoikhet IN, Markin AV. [The specific features of respiratory support in patients with obstructive sleep apnoea syndrome concurrent with chronic obstructive pulmonary disease (crossing-syndrome)]. Terapevticheskii Arkhiv. 2010;82(3):26–8. PMID: 20564917. [Foreign language study].20564917
808 Shtabnitskiy V, Brylev L. Non-invasive ventilation for ALS with respiratory failure in home care settings. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841370. [Abstract/conference proceeding].
809 Sidhu M, Davison A, Powrie D, . A 20 year experience of home non-invasive ventilation (NIV) in a district general hospital and the “growing” problem of obesity. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2011;38(no pagination). PMID: 72117302. [Abstract/conference proceeding].
810 Siew CJ, Sharma N, Sriram K. Home mechanical ventilation for patients with chronic respiratory failure: A regional hospital experience. Respirology. 2017 November;22 (Supplement 3):149. PMID: 619967863. [Abstract/conference proceeding].27641743
811 Silveira MG, Chang-Macchiu P, Perez C, . Home mechanical ventilation in lung transplant patients. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841419. [Abstract/conference proceeding].
812 Simonds AK, Elliott MW. Outcome of domiciliary nasal intermittent positive pressure ventilation in restrictive and obstructive disorders. Thorax. 1995 Jun;50(6):604–9. PMID: 7638799. [Irrelevant comparison or no comparison].7638799
813 Simonds AK, Muntoni F, Heather S, . Impact of nasal ventilation on survival in hypercapnic Duchenne muscular dystrophy. Thorax. 1998 Nov;53(11):949–52. PMID: 10193393. [Irrelevant comparison or no comparison].10193393
814 Simonds AK. Home Mechanical Ventilation: An Overview. Annals of the American Thoracic Society. 2016 Nov;13(11):2035–44. PMID: 27560387. [Irrelevant study design].27560387
815 Simonds AK. Home ventilation. European Respiratory Journal - Supplement. 2003 Nov;47:38s–46s. PMID: 14621116. [Irrelevant study design].14621116
816 Simonds AK. Recent advances in respiratory care for neuromuscular disease. Chest. 2006;130(6):1879–86. [Irrelevant study design].17167012
817 Simonelli C, Paneroni M, Vitacca M. An implementation protocol for noninvasive ventilation prescription: the physiotherapist’s role in an Italian hospital. Respiratory Care. 2013 Apr;58(4):662–8. PMID: 23051649. [Irrelevant patient (age, medical condition)].23051649
818 Sin DD, McAlister FA, Man SFP, . Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. 2003 Nov 05;290(17):2301–12. PMID: 14600189. [Irrelevant intervention (or time frame)].14600189
819 Sinuff T, Keenan SP, Department of Medicine MU. Clinical practice guideline for the use of noninvasive positive pressure ventilation in COPD patients with acute respiratory failure. Journal of Critical Care. 2004 Jun;19(2):82–91. PMID: 15236140. [Irrelevant setting/location].15236140
820 Sivasothy P, Smith IE, Shneerson JM. The effect of ventilatory intervention in acute respiratory failure in motor neurone disease. Thorax. 1996;51(SUPPL. 3). [Abstract/conference proceeding].
821 Skomro RP, Gjevre J, Reid J, . Outcomes of home-based diagnosis and treatment of obstructive sleep apnea. Chest. 2010 Aug;138(2):257–63. PMID: 20173052. [Irrelevant patient (age, medical condition)].20173052
822 Sma N, Khedher A, Fraj N, . Compliance and outcomes of home ventilated chronic hypercapnic respiratory failure: A prospective observational study. Intensive Care Medicine Experimental. Conference: 30th Annual Congress of the European Society of Intensive Care Medicine, ESICM. 2017;5(2 Supplement 1). PMID: 619044221. [Abstract/conference proceeding].
823 Sogukpinar O, Karakurt Z, Altinoz H, . Long-term non-invasive mechanical ventilation improves six minutes walk distance in patients with chronic respiratory failure. Pneumon. 2014 03 Jul;27(3):220–5. PMID: 600214149. [Abstract/conference proceeding].
824 Spataro R, Bono V, Marchese S, . Tracheostomy mechanical ventilation in patients with amyotrophic lateral sclerosis: clinical features and survival analysis. Journal of the Neurological Sciences. 2012 Dec 15;323(1-2):66–70. PMID: 22989611. [Irrelevant intervention (or time frame)].22989611
825 Splaingard ML, Frates RC, Jr H, . Home positive-pressure ventilation. Twenty years’ experience. Chest. 1983 Oct;84(4):376–82. PMID: 6352194. [Published before 1995].6352194
826 Splf Societe de Pneumologie de Langue F. [Guidelines for the clinical management of COPD. Oxygen therapy and long-term ventilatory assistance]. Revue des Maladies Respiratoires. 2003 Jun;20(3 Pt 2):S50–3. PMID: 12910096. [Foreign language study].12910096
827 Stanford G, Parrott H, Bilton D, . Positive pressure-analysing the effect of the addition of non-invasive ventilation (NIV) to home airway clearance techniques (ACT) in adult cystic fibrosis (CF) patients. Physiotherapy Theory & Practice. 2015 May;31(4):270–4. PMID: 25942366. [Irrelevant study design].25942366
828 State University of New York at B. Repeat Emergency Department Visits Among Patients With Asthma and COPD. 2016 January. PMID: NCT02499887. [Irrelevant patient (age, medical condition)].
829 Stein PD, Matta F, Hughes MJ. National trends in home treatment of Acute Pulmonary Embolism. Clinical and Applied Thrombosis/Hemostasis. 2018;24(1):115–21. PMID: 622288521. [Irrelevant intervention (or time frame)].27789604
830 Stevenson R, Angus R, Blanchard M, . Intermediate care - Hospital-at-Home in chronic obstructive pulmonary disease: British Thoracic Society guideline. Thorax. 2007 March;62(3):200–10. PMID: 46579798. [Irrelevant intervention (or time frame)].17090570
831 Stieglitz S, Randerath W. [Weaning failure: follow-up care by the weaning centres-home visits to patients with invasive ventilation]. Pneumologie. 2012 Jan;66(1):39–43. PMID: 22113453. [Foreign language study].22113453
832 Storre JH, Callegari J, Magnet FS, . Home noninvasive ventilatory support for patients with chronic obstructive pulmonary disease: patient selection and perspectives. International Journal of Copd. 2018;13:753–60. PMID: 29535515. [Irrelevant study design].29535515
833 Storre JH, Huttmann SE, Ekkernkamp E, . Oxygen supplementation in noninvasive home mechanical ventilation: the crucial roles of CO2 exhalation systems and leakages. Respiratory Care. 2014 Jan;59(1):113–20. PMID: 23801785. [Irrelevant intervention (or time frame)].23801785
834 Storre JH, Matrosovich E, Ekkernkamp E, . Home mechanical ventilation for COPD: high-intensity versus target volume noninvasive ventilation. Respiratory Care. 2014 Sep;59(9):1389–97. PMID: 25074944. [Irrelevant comparison or no comparison].25074944
835 Storre JH, Seuthe B, Fiechter R, . Average volume-assured pressure support in obesity hypoventilation: A randomized crossover trial. Chest. 2006 Sep;130(3):815–21. PMID: 16963680. [Irrelevant study design].16963680
836 Struik FM, Duiverman ML, Bladder G, . Effects of non-invasive positive pressure ventilation (NIPPV) in stable chronic obstructive pulmonary disease (COPD). Respiratory Medicine: COPD Update. 2008 August;4(3):94–100. PMID: 50208293. [Irrelevant study design].
837 Struik FM, Duiverman ML, Meijer PM, . Volume-targeted versus pressure-targeted noninvasive ventilation in patients with chest-wall deformity: a pilot study. Respiratory Care. 2011 Oct;56(10):1522–5. PMID: 21513604. [Irrelevant outcome].21513604
838 Struik FM, Kerstjens HAM, Bladder G, . Nocturnal noninvasive ventilation in COPD patients who remain hypercapnic after ventilatory support for an acute respiratory failure: A randomized, controlled, parallel-group study. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2014;189(no pagination). PMID: 72043624. [Abstract/conference proceeding].
839 Stuart M, Weinrich M. Protecting the most vulnerable: home mechanical ventilation as a case study in disability and medical care: report from an NIH conference. Neurorehabilitation & Neural Repair. 2001;15(3):159–66. PMID: 11944736. [Irrelevant study design].11944736
840 Su M, Huai D, Cao J, . Auto-trilevel versus bilevel positive airway pressure ventilation for hypercapnic overlap syndrome patients. Sleep and Breathing. 2018 01 Mar;22(1):65–70. PMID: 616797752. [Irrelevant intervention (or time frame)].28612267
841 Sugino K, Tsuboi E, Miyamoto A, . [Efficacy of domiciliary noninvasive positive pressure ventilation in chronic obstructive pulmonary disease patients]. Nihon Kokyuki Gakkai Zasshi. 2008 Jun;46(6):432–7. PMID: 18592986. [Foreign language study].18592986
842 Sundling IM, Ekman SL, Weinberg J, . Patients’ with ALS and caregivers’ experiences of non-invasive home ventilation. Advances in Physiotherapy. 2009;11(3):114–20. PMID: 355791144. [Irrelevant comparison or no comparison].
843 Sunwoo BY, Mulholland M, Rosen IM, . The changing landscape of adult home noninvasive ventilation technology, use, and reimbursement in the United States. Chest. 2014 May;145(5):1134–40. PMID: 24798837. [Irrelevant study design].24798837
844 Suzuki S, Yoshihisa A, Miyata M, . Anemia has significant impacts for adaptive servo ventilation therapy on heart failure patients with Cheyne-Stokes respiration. European Heart Journal. 2012 August;33:481. PMID: 70884221. [Abstract/conference proceeding].
845 Swanton L, Mandal S, Ramsey M, . Home mechanical ventilation (HMV) discontinuation: Mortality, adherence and transfer. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2013;42(no pagination). PMID: 71841416. [Abstract/conference proceeding].
846 Szkulmowski Z. Home mechanical ventilation by the Sue Ryder Ventilation Team in Bydgoszcz. [Polish]. Anestezjologia Intensywna Terapia. 2003;35(3):185–8. PMID: 38489194. [Foreign language study].
847 Takada K, Matsumoto S, Hiramatsu T, . [Predictors of survival in patients with chronic hypercapnic respiratory failure receiving domiciliary NPPV]. Nihon Kokyuki Gakkai Zasshi. 2008 Aug;46(8):614–9. PMID: 18788429. [Foreign language study].18788429
848 Takada K, Matsumoto S, Hiramatsu T, . COPD patients with chronic hypercapnic respiratory failure receiving domiciliary noninvasive positive pressure ventilation - Analysis of prognostic factors and suggestion for supportive system. [Japanese]. Therapeutic Research. 2009;30(9):1491–7. PMID: 355483926. [Foreign language study].
849 Tan GP, McArdle N, Dhaliwal SS, . Patterns of use, survival and prognostic factors in patients receiving home mechanical ventilation in Western Australia: A single centre historical cohort study. Chronic Respiratory Disease. 2018 Jan 01:1479972318755723. PMID: 2941555629415556. [Irrelevant intervention (or time frame)].
850 Tan GP, Soon LHY, Ni B, . Variability of forced expiratory manoeuvre in patients with advanced neuromuscular diseases. Respirology. 2017 November;22 (Supplement 3):151–2. PMID: 619967960. [Abstract/conference proceeding].
851 Tanaka Y, Fukui M, Nakamura F, . [A cross-sectional study of the current status of respiratory home care patients and their caregivers in Osaka Prefecture]. Nihon Kokyuki Gakkai Zasshi. 2011 Aug;49(8):559–68. PMID: 21894770. [Foreign language study].21894770
852 Tang Q, Qin G. [Therapeutic effect of long-term noninvasive positive pressure ventilation on stable chronic obstructive pulmonary disease: a systematic review]. Zhong Nan da Xue Xue Bao Yi Xue Ban = Journal of Central South University Medical Sciences. 2016 Mar 28;41(3):319–27. PMID: 27033798. [Foreign language study].27033798
853 Tanque AAG, Nolido RT, Benedicto JP. Noninvasive positive-pressure ventilation to prevent postextubation respiratory failure: A meta-analysis. Respirology. 2010 November;15:51. PMID: 70313298. [Irrelevant patient (age, medical condition)].20199635
854 Tedeschi E, Carratu P, Damiani MF, . Home unattended portable monitoring and automatic CPAP titration in patients with high risk for moderate to severe obstructive sleep apnea. Respiratory Care. 2013 Jul;58(7):1178–83. PMID: 23051680. [Irrelevant patient (age, medical condition)].23051680
855 Tee V, Osadnik C, Carson K, . Non-invasive positive pressure ventilation for treatment of respiratory failure due to exacerbation of COPD: A cochrane systematic analysis. Respirology. 2015 March;20:37. PMID: 71870692. [Abstract/conference proceeding].
856 Teschler H, Stampa JW, Farhat AA, . [Comparison of the efficacy of the BiPAP-S/T and the VPAP-S/T ventilators in patients with stable chronic respiratory insufficiency]. Pneumologie. 1998 Jun;52(6):305–10. PMID: 9715644. [Foreign language study].9715644
857 Teschler H, Wessendorf TE, Farhat AA, . Two months auto-adjusting versus conventional nCPAP for obstructive sleep apnoea syndrome. European Respiratory Journal. 2000 Jun;15(6):990–5. PMID: 10885414. [Irrelevant patient (age, medical condition)].10885414
858 Tetlow SJ, Marino PS, Murphy PD, . Initiation of long-term non-invasive ventilation (NIV) in a specialist respiratory failure unit in the UK. Thorax. 2016 December;71:A126. PMID: 615030634. [Abstract/conference proceeding].
859 Thammasat U. Patient Characteristics, Feasibility, and Outcomes of a Home Mechanical Ventilation Program in a Developing Country. 2014 November. PMID: NCT02927613. [Irrelevant comparison or no comparison].
860 The Miriam H. The Active Mind Study. 2016 April 1. PMID: NCT03289546. [Abstract/conference proceeding].
861 Thibout Y, Philit F, Freymond N, . [Outcome in COPD patients treated with at-home, long-term, non-invasive ventilation]. Revue des Maladies Respiratoires. 2006 Nov;23(5 Pt 1):438–44. PMID: 17314743. [Foreign language study].17314743
862 Tilanus TBM, Groothuis JT, TenBroek-Pastoor JMC, . The predictive value of respiratory function tests for non-invasive ventilation in amyotrophic lateral sclerosis. Respiratory Research. 2017 Jul 25;18(1):144. PMID: 28743265. [Irrelevant outcome].28743265
863 Tingting X, Luo P, Xin C. Effects of long-term high-intensity noninvasive ventilation on outpatients with stable hypercapnic chronic obstructive pulmonary diseas. Respirology. 2016 November;21:139. PMID: 613436022. [Abstract/conference proceeding].
864 Tissot A, Jaffre S, Gagnadoux F, . Home Non-Invasive Ventilation Fails to Improve Quality of Life in the Elderly: Results from a Multicenter Cohort Study. PLoS ONE [Electronic Resource]. 2015;10(10):e0141156. PMID: 26489014. [Unclear device].26489014
865 Toledo A, Borghi-Silva A, Sampaio LMM, . The impact of noninvasive ventilation during the physical training in patients with moderate-to-severe chronic obstructive pulmonary disease (COPD). Clinics (Sao Paulo, Brazil). 2007 Apr;62(2):113–20. PMID: 17505694. [Irrelevant study design].17505694
866 Toussaint M, Pernet K, Steens M, . Cough Augmentation in Subjects With Duchenne Muscular Dystrophy: Comparison of Air Stacking via a Resuscitator Bag Versus Mechanical Ventilation. Respiratory Care. 2016 Jan;61(1):61–7. PMID: 26443018. [Irrelevant intervention (or time frame)].26443018
867 Toussaint M, Steens M, Wasteels G, . Diurnal ventilation via mouthpiece: survival in end-stage Duchenne patients. European Respiratory Journal. 2006;28(3):549–55. [Irrelevant patient (age, medical condition)].16870671
868 Treuheit T, Bartels C, Hoffmann B, . [Our first experiences with intermittent assisted ventilation in patients with amyotrophic lateral sclerosis]. Pneumologie. 1999 Oct;53: Suppl 2:S86–8. PMID: 10613049. [Foreign language study].10613049
869 Tsai CL, Lee WY, Delclos GL, . Comparative effectiveness of noninvasive ventilation versus invasive mechanical ventilation in chronic obstructive pulmonary disease patients with acute respiratory failure. Academic Emergency Medicine. 2012 April;19:S309. PMID: 70745749. [Abstract/conference proceeding].
870 Tsara V, Serasli E, Voutsas V, . Burden and coping strategies in families of patients under noninvasive home mechanical ventilation. Respiration. 2006;73(1):61–7. PMID: 16106115. [Irrelevant patient (age, medical condition)].16106115
871 Tsuboi T, Aoyama N, Machida K, . Outcome of long-term non-invasive positive-pressure ventilation in 53 patients with hypercapnic respiratory failure. [Japanese]. Japanese Journal of Thoracic Diseases. 1997;35(SUPPL.):139–42. PMID: 28377430. [Foreign language study].28377430
872 Tsuboi T, Oga T, Machida K, . Importance of ventilator mode in long-term noninvasive positive pressure ventilation. Respiratory Medicine. 2009 December;103(12):1854–61. PMID: 50601492. [Unclear device].19660926
873 Tsuboi T, Oga T, Sumi K, . The importance of controlling P<inf>aCO2</inf> throughout long-term noninvasive ventilation. Respiratory Care. 2014 November;59(11):1671–8. PMID: 606851662. [Irrelevant outcome].25233384
874 Tsuboi T, Oga T, Sumi K, . The importance of stabilizing PaCO<inf>2</inf> during long-term non-invasive ventilation in subjects with COPD. Internal Medicine. 2015;54(10):1193–8. PMID: 604419823. [Outcomes not reported per device intervention].25986255
875 Tsuboi T, Ohi M, Oga T, . Importance of the PaCO(2) from 3 to 6 months after initiation of long-term non-invasive ventilation. Respiratory Medicine. 2010 Dec;104(12):1850–7. PMID: 20537881. [Unclear device].20537881
876 Tuggey JM, Delmastro M, Elliott MW. The effect of mouth leak and humidification during nasal non-invasive ventilation. Respiratory Medicine. 2007 Sep;101(9):1874–9. PMID: 17601720. [Irrelevant patient (age, medical condition)].17601720
877 Tuggey JM, Elliott MW. Randomised crossover study of pressure and volume non-invasive ventilation in chest wall deformity. Thorax. 2005 Oct;60(10):859–64. PMID: 16085730. [Irrelevant study design].16085730
878 Tuggey JM, Plant PK, Elliott MW. Domiciliary non-invasive ventilation for recurrent acidotic exacerbations of COPD: An economic analysis. Thorax. 2003 01 Oct;58(10):867–71. PMID: 37239234. [Irrelevant study design].14514940
879 Turan O, Sevinc C. Home non-invasive mechanical ventilation therapy in elderly COPD patients. Turk Geriatri Dergisi. 2015;18(1):15–21. PMID: 603648582. [Irrelevant study design].
880 Twork S, Usicenko S, Koch R, . Directing ventilator settings for home-ventilated patients by artificial neural networks. [German]. Monatsschrift fur Kinderheilkunde. 2003 01 Mar;151(3):274–83. PMID: 36612752. [Foreign language study].
881 Twork S, Usičenko S, Koch R, . Directing ventilator settings for home-ventilated patients by artificial neural networks. Monatsschrift fur Kinderheilkunde. 2003;151(3):274–83. [Foreign language study].
882 Tzeng AC, Bach JR. Prevention of pulmonary morbidity for patients with neuromuscular disease. Chest. 2000 Nov;118(5):1390–6. PMID: 11083691. [Irrelevant patient (age, medical condition)].11083691
883 Umarova I, Balionis O, Gorelov A. The efficacy of noninvasive positive pressure ventilation in patients with obesity hypoventilation syndrome according to the android/gynoid fat ratio and position of ventilation. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105961. [Abstract/conference proceeding].
884 Umpleby H, Oliver D, Banerjee S, . A novel collaborative approach in improving management outcomes in patients with motor neurone disease (MND). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2015;46(no pagination). PMID: 72105999. [Abstract/conference proceeding].
885 United States Naval Medical C, San D, Office of Naval R, . Stress Resilience Training System. 2012 October. PMID: NCT01599624. [Irrelevant patient (age, medical condition)].
886 Universidad Autonoma de M. Effects of Manual Therapy and Respiratory Muscle Training on the Maximal Inspiratory Pressure in Patients With Asthma. 2015 December. PMID: NCT02690831. [Irrelevant patient (age, medical condition)].
887 Universidad Autonoma de M. Video Game Exercise Effectiveness of a Domiciliary Pulmonary Rehabilitation Program in Cystic Fibrosis Patients. 2015 July. PMID: NCT02552043. [Irrelevant intervention (or time frame)].
888 Universidad de G. Physiotherapy in Patients With Stable Chronic Obstructive Pulmonary Disease. 2015 September. PMID: NCT02517411. [Irrelevant intervention (or time frame)].
889 Università degli Studi di F. Exercise Training in Chronic Obstructive Pulmonary Disease (COPD). 2008 January. PMID: NCT01218282. [Irrelevant patient (age, medical condition)].
890 University Health Network T. Effects of Remote Patient Monitoring on Chronic Disease Management. 2016 August 23. PMID: NCT03127852. [Irrelevant patient (age, medical condition)].
891 University Health Network T. Protective Mechanical VENTilation Strategy in Patients Undergoing CARDiac Surgery. 2017 July 7. PMID: NCT03288558. [Abstract/conference proceeding].
892 University Hospital G. COPD-EXA-REHAB. Early Pulmonary Rehabilitation of Patients With Acute Exacerbation of COPD. 2013 November. PMID: NCT02987439. [Irrelevant intervention (or time frame)].
893 University Hospital M. Effects of a Therapeutic Education Program on Treatment Adherence Among Patients Prescribed At-home CPAP or At-home NIV. 2017 May 12. PMID: NCT03151317. [Completed Clinical Trial].
894 University Hospital of South Manchester NHSFT, University of M, Imperial College L, . The Use of Home-monitoring and mHealth Systems to Predict Asthma Control and the Occurrence of Asthma Exacerbations. 2016 April. PMID: NCT02774772. [Irrelevant patient (age, medical condition)].
895 University Hospital R. Change in Breathing Pattern on Non-invasive Ventilation of COPD Patients Under Home Mechanical Ventilation. 2017 January. PMID: NCT03018470. [Irrelevant comparison or no comparison].
896 University Hospital R. Home Non Invasive Ventilation for COPD Patients. 2011 December. PMID: NCT03221101. [Completed Clinical Trial].
897 University Hospital R. Home Non-invasive Ventilation for Chronic Obstructive Pulmonary Disease Patients. 2011 December. PMID: NCT01526642. [Irrelevant study design].
898 University of Alabama at Birmingham UoC, San Francisco VAOoR, Development UoM. IVR-Enhanced Care Transition Support for Complex Patients. 2010 February. PMID: NCT01135381. [Irrelevant intervention (or time frame)].
899 University of C. The Effect of Yoga on Cardiac Sympathetic Innervation Evaluated by I-123 mIBG. 2017 August 31. PMID: NCT03227393. [Irrelevant patient (age, medical condition)].
900 University of D, Chiesi Farmaceutici SpA. Effects of Particle Size in Small Airways Dysfunction. 2013 July. PMID: NCT01892787. [Irrelevant patient (age, medical condition)].
901 University of F. Expiratory Muscle Training in Patients With Parkinson’s Disease. 2004 January. PMID: NCT00843739. [Irrelevant patient (age, medical condition)].
902 University of M. Home-Based Diagnosis and Management of Sleep-Related Breathing Disorders in Spinal Cord Injury. 2011 October. PMID: NCT01882257. [Completed Clinical Trial].
903 University of M-C, Tyco Healthcare G. Prospective Study Comparing Different Modalities of Oxygen Delivery During Assessment of Functional Exercise Capacity. 2006 May. PMID: NCT00484562. [Irrelevant intervention (or time frame)].
904 University of W. Stroke and CPAP Outcome Study 2. 2016 June. PMID: NCT02809430. [Irrelevant patient (age, medical condition)].
905 University of Wisconsin M. Brief Trainings to Buffer Against Acute Stress Effects. 2014 October. PMID: NCT02214264. [Irrelevant patient (age, medical condition)].
906 University RA. SAS in Patients With Bronchial Carcinoma. 2014 April. PMID: NCT02270853. [Irrelevant patient (age, medical condition)].
907 Use of Respiratory Therapists (RTs) to Improve Outcomes and Quality of Life in Patients With COPD. 2014 March. PMID: NCT02078622. [Irrelevant patient (age, medical condition)].
908 Valensi PL. [Monitoring patient treated by continuous positive pressure: recommendations of the SPLF group]. Revue des Maladies Respiratoires. 2000 Jun;17(3):709–11. PMID: 10951971. [Abstract/conference proceeding].10951971
909 Van Gestel A, Horner M, Brutsche M, . Cardiopulmonary- and hemodynamic responses during Non-Invasive positive airway pressure ventilation in patients with chronic obstructive pulmonary disease. Respiration. 2016;91 (5):433. PMID: 611888136. [Abstract/conference proceeding].
910 van Kesteren RG, Kampelmacher MJ, Dullemond-Westland AC, . [Favorable results of nocturnal nasal positive-pressure ventilation in 64 patients with neuromuscular disorders; 5-year experience]. Nederlands Tijdschrift voor Geneeskunde. 1994 Sep 10;138(37):1864–8. PMID: 7935923. [Published before 1995].7935923
911 Van Kesteren RG, Kampelmacher MJ, Dullemond-Westland AC, . Favourable effects of nightly nasal positive pressure ventilation in 64 patients with neuromuscular disorders; 5 years’ experience. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1994;138(37):1864–8. PMID: 24285636. [Published before 1995].7935923
912 Van Kesteren RG, Velthuis B, Van Leyden LW. Psychosocial problems arising from home ventilation. American Journal of Physical Medicine and Rehabilitation. 2001;80(6):439–45. PMID: 32520306. [Irrelevant intervention (or time frame)].11399005
913 Veale D, Gonzalez-Bermejo J, Borel JC, . [Initiation of long-term non-invasive ventilation at home: current practices and expected issues. Surveys from the CasaVNI working party]. Revue des Maladies Respiratoires. 2010 Nov;27(9):1022–9. PMID: 21111272. [Foreign language study].21111272
914 Viale JP, Duperret S, Mahul P, . Time course evolution of ventilatory responses to inspiratory unloading in patients. American Journal of Respiratory & Critical Care Medicine. 1998 Feb;157(2):428–34. PMID: 9476854. [Irrelevant intervention (or time frame)].9476854
915 Vianello A, Savoia F, Pipitone E, . “Hospital at home” for neuromuscular disease patients with respiratory tract infection: A pilot study. Respiratory Care. 2013 01 Dec;58(12):2061–8. PMID: 370322102. [Irrelevant comparison or no comparison].23696687
916 Vianello A, Semplicini C, Paladini L, . Enzyme replacement therapy improves respiratory outcomes in patients with late-onset type II glycogenosis and high ventilator dependency. Lung. 2013 Oct;191(5):537–44. PMID: 23839583. [Irrelevant patient (age, medical condition)].23839583
917 Vitacca M, Assoni G, Pizzocaro P, . A pilot study of nurse-led, home monitoring for patients with chronic respiratory failure and with mechanical ventilation assistance. Journal of Telemedicine & Telecare. 2006;12(7):337–42. PMID: 17059649. [Irrelevant comparison or no comparison].17059649
918 Vitacca M, Barbano L, Colombo D, . Prevalence and variability of use of home mechanical ventilators, positive airway pressure and oxygen devices in the Lombardy region, Italy. Monaldi Archives for Chest Disease. 2018 Jan 29;88(1):882. PMID: 29557574. [Irrelevant comparison or no comparison].29557574
919 Vitacca M, Barbano L, D’Anna S, . Comparison of five bilevel pressure ventilators in patients with chronic ventilatory failure: a physiologic study. Chest. 2002 Dec;122(6):2105–14. PMID: 12475854. [Outcomes not reported per device intervention].12475854
920 Vitacca M, Bianchi L, Bazza A, . Advanced COPD patients under home mechanical ventilation and/or long term oxygen therapy: Italian healthcare costs. Monaldi Archives for Chest Disease. 2011 Dec;75(4):207–14. PMID: 22462308. [Irrelevant intervention (or time frame)].22462308
921 Vitacca M, Bianchi L, Guerra A, . Tele-assistance in chronic respiratory failure patients: a randomised clinical trial. European Respiratory Journal. 2009 Feb;33(2):411–8. PMID: 18799512. [Irrelevant intervention (or time frame)].18799512
922 Vitacca M, Escarrabill J, Galavotti G, . Home mechanical ventilation patients: a retrospective survey to identify level of burden in real life. Monaldi Archives for Chest Disease. 2007 Sep;67(3):142–7. PMID: 18018753. [Irrelevant intervention (or time frame)].18018753
923 Vitacca M, Guerra A, Pizzocaro P, . Time consuming of physicians and nurses before discharge in patients with chronic respiratory failure submitted to home mechanical ventilation. [Italian]. Rassegna di Patologia dell’Apparato Respiratorio. 2005 December;20(6):275–83. PMID: 43651303. [Foreign language study].
924 Vitacca M, Kaymaz D, Lanini B, . Non-invasive ventilation during cycle exercise training in patients with chronic respiratory failure on long-term ventilatory support: A randomized controlled trial. Respirology. 2018 Feb;23(2):182–9. PMID: 28940820. [Irrelevant intervention (or time frame)].28940820
925 Vitacca M, Lanini B, Nava S, . Inspiratory muscle workload due to dynamic intrinsic PEEP in stable COPD patients: Effects of two different settings of non-invasive pressure-support ventilation. Monaldi Archives for Chest Disease - Pulmonary Series. 2004 April/June;61(2):81–5. PMID: 39386838. [Irrelevant intervention (or time frame)].
926 Vitacca M, Nava S, Confalonieri M, . The appropriate setting of noninvasive pressure support ventilation in stable COPD patients. Chest. 2000 Nov;118(5):1286–93. PMID: 11083676. [Irrelevant comparison or no comparison].11083676
927 Volpato E, Banfi P, Pagnini F. A psychological intervention to promote acceptance and adherence to non-invasive ventilation in people with chronic obstructive pulmonary disease: Study protocol of a randomised controlled trial. Trials. 2017;18(1). [Irrelevant study design].
928 Vrijsen B, Buyse B, Belge C, . Randomized cross-over trial of ventilator modes during non-invasive ventilation titration in amyotrophic lateral sclerosis. Respirology. 2017 Aug;22(6):1212–8. PMID: 28374969. [Irrelevant outcome].28374969
929 Wake Forest U, Wake Forest University Health S. Supportive Intervention Programs Study. 2011 June. PMID: NCT01590147. [Irrelevant patient (age, medical condition)].
930 Wang CG, Liu Y, Cao Z. Sequential non invasive ventilation (NIV) following short term invasive ventilation (IV) in COPD induced hypercapnic respiratory failure-the concept of pulmonary infection control window (PIC window) and its value for being used as the switching point: a prospective, randomised controlled study [Abstract]. European respiratory journal. 2003;22:(Suppl 45):Abstract P2599. PMID: CN-00486358 UPDATE. [Abstract/conference proceeding].
931 Wang H-l, He Z-m, Li J, . [Effect of noninvasive ventilation on chemoresponsiveness in patients with sleep apnea and chronic obstructive pulmonary disease]. Chung-Hua i Hsueh Tsa Chih [Chinese Medical Journal]. 2007 Aug 21;87(31):2193–7. PMID: 18001529. [Foreign language study].18001529
932 Ward EM, Bestall JC, Seemungal TR, . Randomised crossover study of inspiratory positive airway pressure on gas exchange and dyspnoea during nasal ventilation in stable COPD. Thorax. 1996;51(SUPPL. 3). [Abstract/conference proceeding].
933 Ward K, Ashcroft H, Ford V, . Inpatient transfer for commencement of home NIV: Does a proforma improve practice? European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614777786. [Abstract/conference proceeding].
934 Ward S, Chatwin M, Heather S, . Randomised controlled trial of non-invasive ventilation (NIV) for nocturnal hypoventilation in neuromuscular and chest wall disease patients with daytime normocapnia. Thorax. 2005;60(12):1019–24. [Irrelevant patient (age, medical condition)].16299118
935 Watling L, Kohli R, Goldstein R, . Improving transitions to the community for ventilator assisted individuals using telemedicine technology. Chest. Conference: CHEST World Congress. 2014;145(3 MEETING ABSTRACT). PMID: 71428810. [Abstract/conference proceeding].
936 Wawruszak M, Churchward T, Copland J, . Comparative study of two titrating cpap devices in the home setting. [abstract]. Internal medicine journal. 2005;35. PMID: CN-00584194 UPDATE. [Abstract/conference proceeding].
937 Wedzicha JAEC-C, Miravitlles M, Hurst JR, . Management of COPD exacerbations: a European Respiratory Society/American Thoracic Society guideline. European Respiratory Journal. 2017 Mar;49(3). PMID: 28298398. [Irrelevant setting/location].28298398
938 Weerasuriya C, Wozniak D, Huq S, . Predictors of mortality for patients with obesity-related respiratory failure treated with nocturnal non-invasive ventilation. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614778026. [Abstract/conference proceeding].
939 Werpachowska A, Inayat B, Howard M, . One-year experience of domiciliary non-invasive ventilation (NIV) monitoring via wireless modem in a district general hospital (DGH). European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2016;48(no pagination). PMID: 614780391. [Abstract/conference proceeding].
940 West NE. Treatment of pulmonary exacerbations. Pediatric pulmonology. 2017; Conference: 31st annual north american cystic fibrosis conference. United states. 52(Supplement 47):124–6. PMID: CN-01430915 NEW. [Abstract/conference proceeding].
941 West SD, Anderson K, Hartley J, . A regional respiratory and sleep assessment service for people with myotonic dystrophy. American Journal of Respiratory and Critical Care Medicine. Conference: American Thoracic Society International Conference, ATS. 2013;187(no pagination). PMID: 71981408. [Abstract/conference proceeding].
942 Wiebel M, Schulz M, Herth F, . [Follow-up of intermittent self-ventilation (ISB). Mortality and causes]. Medizinische Klinik. 1997 Apr 28;92 Suppl 1:63–7. PMID: 9235478. [Foreign language study].9235478
943 Wiebel M, Schulz M, Herth F, . Course of IPPV: Causes of mortality. [German]. Medizinische Klinik. 1997 28 Apr;92(SUPPL. 1):63–7. PMID: 27225942. [Foreign language study].27225942
944 Wijkstra PJ, Lacasse Y, Guyatt GH, . A meta-analysis of nocturnal non-invasive positive pressure ventilation (NIPPV) in stable patients with chronic obstructive pulmonary disease. European respiratory journal. 2001;18:(Suppl 33):402s. PMID: CN-00430687 UPDATE. [Abstract/conference proceeding].
945 Williams TA, Finn J, Perkins GD, . Prehospital continuous positive airway pressure for acute respiratory failure: a systematic review and meta-analysis. Prehospital Emergency Care. 2013 Apr-Jun;17(2):261–73. PMID: 23373591. [Irrelevant patient (age, medical condition)].23373591
946 Willson GN, Piper AJ, Norman M, . Nasal versus full face mask for noninvasive ventilation in chronic respiratory failure. European Respiratory Journal. 2004 Apr;23(4):605–9. PMID: 15083762. [Irrelevant outcome].15083762
947 Windisch W, Brambring J, Budweiser S, . [Non-invasive and invasive mechanical ventilation for treatment of chronic respiratory failure. S2-Guidelines published by the German Medical Association of Pneumology and Ventilatory Support]. Pneumologie. 2010 Apr;64(4):207–40. PMID: 20376768. [Foreign language study].20376768
948 Windisch W, Dreher M, Geiseler J, . [Guidelines for Non-Invasive and Invasive Home Mechanical Ventilation for Treatment of Chronic Respiratory Failure - Update 2017]. Pneumologie. 2017 Nov;71(11):722–95. PMID: 29139100. [Foreign language study].29139100
949 Windisch W, Freidel K, Schucher B, . Evaluation of health-related quality of life using the MOS 36-Item Short-Form Health Status Survey in patients receiving noninvasive positive pressure ventilation. Intensive Care Medicine. 2003 Apr;29(4):615–21. PMID: 12618917. [Unclear device].12618917
950 Windisch W, Kostie S, Dreher M, . Outcome of patients with stable COPD receiving controlled noninvasive positive pressure ventilation aimed at a maximal reduction of PACO<inf>2</inf>. [Portuguese]. Revista Portuguesa de Pneumologia. 2006 May/June;12(3):309–11. PMID: 44131936. [Foreign language study].
951 Windisch W, Petermann F, Laier-Groeneveld G, . [Quality of life in home ventilation]. Medizinische Klinik. 1997 Apr 28;92 Suppl 1:95–100. PMID: 9235487. [Foreign language study].9235487
952 Windisch W, Quality of life in home mechanical ventilation study g. Impact of home mechanical ventilation on health-related quality of life. European Respiratory Journal. 2008 Nov;32(5):1328–36. PMID: 18579546. [Outcomes not reported per device intervention].18579546
953 Windisch W, Storre JH, Sorichter S, . Comparison of volume- and pressure-limited NPPV at night: a prospective randomized cross-over trial. Respiratory Medicine. 2005 Jan;99(1):52–9. PMID: 15672849. [Irrelevant study design].15672849
954 Windisch W. [Recent developments in home mechanical ventilation]. Deutsche Medizinische Wochenschrift. 2012 Mar;137(13):656–8. PMID: 22434175. [Foreign language study].22434175
955 Winterholler M, Claus D, Bockelbrink A, . [Home ventilation in neuromuscular diseases in adults. Presentation of recommendations of the Bavarian Muscle Centers of the DGM]. Medizinische Klinik. 1996 Apr 12;91 Suppl 2:45–7. PMID: 8684325. [Foreign language study].8684325
956 Winterholler M, Claus D, Bockelbrink A, . [Recommendations of Bavarian Muscle Centers of the German Neuromuscular Disease Society for home ventilation of neuromuscular diseases of adult patients]. Nervenarzt. 1997 Apr;68(4):351–7. PMID: 9273467. [Foreign language study].9273467
957 Winterholler MG, Erbguth FJ, Hecht MJ, . [Survival with artificial respiration at home. An open, prospective study on home ventilation for neuromuscular diseases, in particular, the situation of ALS patients]. Nervenarzt. 2001 Apr;72(4):293–301. PMID: 11320865. [Abstract/conference proceeding].11320865
958 Winterholler MGM, Erbguth FJ, Hecht MJ, . Living beyond respiratory failure with neuromuscular disease - An open, prospective 6-year trial on the long-term effects and complications of home ventilation. [German]. Nervenarzt. 2001;72(4):293–301. PMID: 32288973. [Foreign language study].11320865
959 Wissenschaftliches Institut Bethanien e V. Course and Complications of Invasive Out-of-hospital Ventilation. 2009 January. PMID: NCT01755039. [Irrelevant intervention (or time frame)].
960 Woehrle H, Ficker JH, Graml A, . Telemedicine-based proactive patient management during positive airway pressure therapy: Impact on therapy termination rate. Somnologie. 2017;21(2):121–7. PMID: 28706464. [Outcomes not reported per device intervention].28706464
961 Wohlgemuth M, van der Kooi EL, van Kesteren RG, . Ventilatory support in facioscapulohumeral muscular dystrophy. Neurology. 2004 Jul 13;63(1):176–8. PMID: 15249635. [Irrelevant comparison or no comparison].15249635
962 Wolf E, Penchas S, Werczberger A, . Home care therapy for respirator-dependent patients. Israel Journal of Medical Sciences. 1993;29(10):617–23. PMID: 23301395. [Published before 1995].8244658
963 Wong D, Jones S. Obesity hypoventilation syndrome (OHS): The presentations and outcomes of 79 inpatients. Sleep and Biological Rhythms. 2013 October;11:59. PMID: 71226715. [Abstract/conference proceeding].
964 Wong KM, Lam YP, Lo HY, . A collaborative haven (home assisted ventilation enhancement network) programme to shorten length of Hospital stay for tracheostomised patients with or without mechanical ventilation. Respirology. 2012 December;17:33. PMID: 71376037. [Abstract/conference proceeding].
965 Worsley D, Telford F, Land DB. Home mechanical ventilation: Has ventilator technology surpassed our ability to care for some patients in a community setting? Thorax. 2014 December;69:A206–A7. PMID: 71689066. [Abstract/conference proceeding].
966 Wright GR, Howieson S, McSharry C, . Effect of improved home ventilation on asthma control and house dust mite allergen levels. Allergy. 2009 Nov;64(11):1671–80. PMID: 19650848. [Irrelevant patient (age, medical condition)].19650848
967 Wylie PE, Pegram V, Rosenberg R, . Home-use servo ventilation therapy in chronic pain patients with sleep disordered breathing. Sleep. 2013;36:A149. PMID: 71513243. [Abstract/conference proceeding].
968 Xiang P-c, Yang H, Guo W-a, . [The clinical application of bi-level positive airway pressure noninvasive ventilator for home mechanical ventilation via tracheostomy in patients with amyotrophic lateral sclerosis]. Chung-Hua Chieh Ho Ho Hu Hsi Tsa Chih Chinese Journal of Tuberculosis & Respiratory Diseases. 2009 Feb;32(2):107–10. PMID: 19567181. [Foreign language study].19567181
969 Xiang P-c, Zhang X, Yang J-n, . [The efficacy and safety of long term home noninvasive positive pressure ventilation in patients with stable severe chronic obstructive pulmonary disease]. Chung-Hua Chieh Ho Ho Hu Hsi Tsa Chih Chinese Journal of Tuberculosis & Respiratory Diseases. 2007 Oct;30(10):746–50. PMID: 18218204. [Foreign language study].18218204
970 Xu XP, Zhang XC, Hu SL, . Noninvasive Ventilation in Acute Hypoxemic Nonhypercapnic Respiratory Failure: A Systematic Review and Meta-Analysis. Critical Care Medicine. 2017;45(7):e727–e33. [Irrelevant patient (age, medical condition)].28441237
971 Yale University RWJF, ResMed Foundation VAOoR. Diagnosis and Treatment of Sleep-Disordered Breathing in the Homes of Patients With Transient Ischemic Attack. 2004 November. PMID: NCT00251290. [Irrelevant patient (age, medical condition)].
972 Yamauchi R, Imai T, Tsuda E, . Respiratory insufficiency with preserved diaphragmatic function in amyotrophic lateral sclerosis. Internal Medicine. 2014;53(12):1325–31. PMID: 373312474. [Irrelevant outcome].24930652
973 Yang L, Nonoyama M, Pizzuti R, . Home mechanical ventilation: A retrospective review of safety incidents using the World Health Organization International Patient Safety Event classification. Canadian Journal of Respiratory Therapy. 2016;52(3):85–91. PMID: 613687570. [Irrelevant study design].30123023
974 Yang S-y, Shen J-l, Feng E-z. [Study on the indication and time of the use of non-invasive positive pressure ventilation in the patients with acute exacerbation of chronic cor pulmonale combined with type II respiratory failure at high altitude area]. Zhongguo Wei Zhong Bing Ji Jiu Yi Xue/Chinese Critical Care Medicine/Zhongguo Weizhongbing Jijiuyixue. 2009 Jul;21(7):440–1. PMID: 19615142. [Foreign language study].19615142
975 Yavsan M, Goktepe M, Tosun M, . Red cell distribution width and mean platelet volume as a non-invasive ventilation success marker in COPD with acute hypercapnic respiratory failure. European Respiratory Journal. Conference: European Respiratory Society Annual Congress. 2014;44(no pagination). PMID: 71849060. [Abstract/conference proceeding].
976 Yokoi D, Atsuta N, Hirakawa A, . The effect of noninvasive positive pressure ventilation in amyotrophic lateral sclerosis patients from a Japanese multicenter prospective cohort. Journal of the Neurological Sciences. 2017 October;381 (Supplement 1):720–1. PMID: 620185226. [Abstract/conference proceeding].
977 Young AC, Wilson JW, Kotsimbos TC, . Randomized placebo-controlled trial of non-invasive ventilation for hypercapnia in cystic fibrosis [abstract]. Japanese Society of Sleep Research Conference. A9 A10p. 2006. PMID: CN-00593078 UPDATE. [Irrelevant study design].
978 Zaccaria S, Ioli F, Lusuardi M, . Long-term nocturnal mechanical ventilation in patients with kyphoscoliosis. Monaldi Archives for Chest Disease. 1995 Dec;50(6):433–7. PMID: 8834951. [Irrelevant intervention (or time frame)].8834951
979 Zaccaria S, Zaccaria E, Zanaboni S, . Home mechanical ventilation in kyphoscoliosis. Monaldi Archives for Chest Disease. 1993;48(2):161–4. PMID: 8518779. [Published before 1995].8518779
980 Zamietra K, Lehman EB, Felgoise SH, . Non-invasive ventilation and gastrostomy may not impact overall quality of life in patients with ALS. Amyotrophic Lateral Sclerosis. 2012 Jan;13(1):55–8. PMID: 22214353. [Irrelevant comparison or no comparison].22214353
981 Zargaj A, Ziherl K, Sarc I. Gender differences in adherence to noninvasive ventilation in obesity hypoventilation syndrome patients. Journal of Sleep Research. 2016 September;25:354. PMID: 612113189. [Abstract/conference proceeding].
982 Zeng X-Y, Wang X-P, He S-P, . [Clinical effect of bi-level positive airway pressure ventilation on pulmonary encephalopathy of respiratory failure in acute exacerbation of chronic obstructive pulmonary disease]. Zhongguo Wei Zhong Bing Ji Jiu Yi Xue/Chinese Critical Care Medicine/Zhongguo Weizhongbing Jijiuyixue. 2007 Sep;19(9):558–9. PMID: 17767832. [Foreign language study].17767832
983 Zhang B, Wang RM, Liu Y, . Effects of long-term home non-invasive positive pressure ventilation on the pulmonary function and quality of life in patients with chronic respiratory failure. [Chinese]. Chinese Journal of Clinical Rehabilitation. 2005 21 Apr;9(15):33–5. PMID: 41576203. [Foreign language study].
984 Zhou X, Yang J, Shen C. Effect of non-invasive positive pressure ventilation and long-term oxygen therapy in patients with stable COPD. Clin Med J China. 2008;15(4):486–8. [Foreign language study].
985 Zorin E, Vostrukhova S, Egiev V, . CPAP-therapy as the functional foreplay for patients with morbid obesity previous to bariatric surgery. Obesity Surgery. 2014 August;24 (8):1208. PMID: 71586239. [Abstract/conference proceeding].