# Appendix B Search Strategy

## Search Strategy 1

### Ovid

Database(s): Embase 1988 to 2018 Week 26, EBM Reviews - Cochrane Central Register of Controlled Trials May 2018, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to June 20, 2018, Ovid MEDLINE(R) Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) 1946 to Present

[underlined: Search Strategy:]

# | Searches
1 | *noninvasive ventilation/ or exp *positive-pressure respiration/
2 | (BiPAP or BPAP or CPAP or “noninvasive positive pressure ventilation” or “non-invasive positive pressure ventilation” or “noninvasive ventilation” or “non-invasive ventilation” or NPPV or “Positive Airway Pressure*” or “positive end-expiratory pressure*”).ti.
3 | 1 or 2
4 | *Amyotrophic Lateral Sclerosis/
5 | *Bronchiectasis/
6 | *Cystic Fibrosis/
7 | *Hypercapnia/
8 | *Hypoventilation/
9 | *Idiopathic Pulmonary Fibrosis/
10 | *Lung Diseases, Interstitial/
11 | *Pulmonary Fibrosis/
12 | *Idiopathic Pulmonary Fibrosis/
13 | *Kyphosis/
14 | *Obesity/
15 | *Respiratory Insufficiency/
16 | *Scoliosis/
17 | *Spinal Cord Injuries/
18 | *Obesity Hypoventilation Syndrome/
19 | *respiratory failure/
20 | *Lung Diseases, Obstructive/
21 | *Pulmonary Disease, Chronic Obstructive/
22 | *Neuromuscular Diseases/
23 | *Motor Neuron Disease/
24 | *Muscular Atrophy, Spinal/
25 | *Muscular Diseases/
26 | *Muscular Disorders, Atrophic/
27 | *Myopathies, Structural, Congenital/
28 | *Myositis/
29 | *Myotonic Disorders/
30 | (“Amyotrophic lateral sclerosis” or “Atrophic Muscular Disorder*” or Bronchiectasis or “Chronic Obstructive Pulmonary Disease*” or “congenital structual myopath*” or “Cystic Fibrosis” or hypercapnia or hypoventilation or “Interstitial Lung Disease*” or kyphosis or “Motor Neuron Disease*” or “Muscular Disease*” or Myositis or “Myotonic Disorder*” or “Neuromuscular Disease*” or Obesity or “obstructive lung disease*” or “Pulmonary fibrosis” or “respiratory failure” or “respiratory insufficiency” or scoliosis or “Spinal Cord Injur*” or “Spinal Muscular Atrophy” or “structural congenital myopath*”).ti.
31 | or/4-30
32 | 3 and 31
33 | limit 32 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) [Limit not valid in Embase,CCTR,CDSR; records were retained]
34 | limit 33 to (adult <18 to 64 years> or aged <65+ years>) [Limit not valid in CCTR,CDSR,Ovid MEDLINE(R),Ovid MEDLINE(R) Daily Update,Ovid MEDLINE(R) In-Process,Ovid MEDLINE(R) Publisher; records were retained]
35 | limit 32 to (“all infant (birth to 23 months)” or “all child (0 to 18 years)” or “newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)”) [Limit not valid in Embase,CCTR,CDSR; records were retained]
36 | limit 35 to (embryo or infant or child or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) [Limit not valid in CCTR,CDSR,Ovid MEDLINE(R),Ovid MEDLINE(R) Daily Update,Ovid MEDLINE(R) In-Process,Ovid MEDLINE(R) Publisher; records were retained]
37 | 36 not 34
38 | 32 not 37
39 | exp Guideline/ or exp Practice Guideline/
40 | exp meta analysis/
41 | exp Meta-Analysis as Topic/
42 | exp “systematic review”/
43 | exp controlled study/
44 | exp Randomized Controlled Trial/
45 | exp triple blind procedure/
46 | exp Double-Blind Method/
47 | exp Single-Blind Method/
48 | exp latin square design/
49 | exp comparative study/
50 | exp Cohort Studies/
51 | exp longitudinal study/
52 | exp retrospective study/
53 | exp prospective study/
54 | exp population research/
55 | exp observational study/
56 | clinical study/
57 | exp Evaluation Studies/
58 | exp quantitative study/
59 | exp validation studies/
60 | exp quasi experimental study/
61 | exp field study/
62 | in vivo study/
63 | exp panel study/
64 | exp prevention study/
65 | exp replication study/
66 | exp Feasibility Studies/
67 | exp trend study/
68 | exp correlational study/
69 | exp case-control studies/
70 | exp confidence interval/
71 | exp regression analysis/
72 | exp proportional hazards model/
73 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or “consensus development” or guideline* or “position statement*” or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (random* adj1 allocat*) or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or multivariate or “comparative study” or “comparative survey” or “comparative analysis” or (intervention* adj2 study) or (intervention* adj2 trial) or crossover or “cross-over” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or (population adj3 (stud* or survey* or analys* or research)) or “concurrent study” or “concurrent survey” or “concurrent analysis” or “incidence study” or “incidence survey” or “incidence analysis” or ((“follow-up” or followup) adj (stud* or survey or analysis)) or ((observation or observational) adj (study or survey or analysis)) or “clinical study” or “clinical trial” or “evaluation study” or “evaluation survey” or “evaluation analysis” or “quantitative study” or “quantitative analys*” or “numerical study” or “validation study” or “validation survey” or “validation analysis” or “quasi experimental study” or “quasi experimental analysis” or “quasiexperimental study” or “quasiexperimental analysis” or “field study” or “field survey” or “field analysis” or “in vivo study” or “in vivo analysis” or “panel study” or “panel survey” or “panel analysis” or ((prevention or preventive) adj3 (trial or study or analysis or survey)) or “replication study” or “replication analysis” or “replication trial” or “feasibility study” or “feasibility analysis” or “trend study” or “trend survey” or “trend analysis” or ((correlation* adj2 study) or (correlation* adj2 analys*)) or “case control study” or “case base study” or “case referrent study” or “case referent study” or “case referent study” or “case compeer study” or “case comparison study” or “matched case control” or “multicenter study” or “multicenter study” or “odds ratio” or “confidence interval” or (hazard* adj (model* or analys* or regression or ratio or ratios)) or “Cox model” or “Cox multivariate analyses” or “Cox multivariate analysis” or “Cox regression” or “Cox survival analyses” or “Cox survival analysis” or “Cox survival model” or “change analysis” or ((study or trial or random* or control*) and compar*)).mp,pt.
74 | or/39-73
75 | 38 and 74
76 | limit 75 to (editorial or erratum or letter or note or addresses or autobiography or bibliography or biography or blogs or comment or dictionary or directory or interactive tutorial or interview or lectures or legal cases or legislation or news or newspaper article or overall or patient education handout or periodical index or portraits or published erratum or video-audio media or webcasts) [Limit not valid in Embase,CCTR,CDSR,Ovid MEDLINE(R),Ovid MEDLINE(R) Daily Update,Ovid MEDLINE(R) In-Process,Ovid MEDLINE(R) Publisher; records were retained]
77 | from 76 keep 130-138
78 | (75 not 76) or 77
79 | limit 78 to yr=“1995 - Current”
80 | remove duplicates from 79

### Scopus

1. TITLE(BiPAP or BPAP or CPAP or “noninvasive positive pressure ventilation” or “non-invasive positive pressure ventilation” or “noninvasive ventilation” or “non-invasive ventilation” or NPPV or “Positive Airway Pressure*” or “positive end-expiratory pressure*”)
2. TITLE(“Amyotrophic lateral sclerosis” or “Atrophic Muscular Disorder*” or Bronchiectasis or “Chronic Obstructive Pulmonary Disease*” or “congenital structual myopath*” or “Cystic Fibrosis” or hypercapnia or hypoventilation or “Interstitial Lung Disease*” or kyphosis or “Motor Neuron Disease*” or “Muscular Disease*” or Myositis or “Myotonic Disorder*” or “Neuromuscular Disease*” or Obesity or “obstructive lung disease*” or “Pulmonary fibrosis” or “respiratory failure” or “respiratory insufficiency” or scoliosis or “Spinal Cord Injur*” or “Spinal Muscular Atrophy” or “structural congenital myopath*”)
3. TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or “consensus development” or guideline* or “position statement*” or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (random* W/1 allocat*) or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or multivariate or “comparative study” or “comparative survey” or “comparative analysis” or (intervention* W/2 study) or (intervention* W/2 trial) or crossover or “cross-over” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or (population W/3 (stud* or survey* or analys* or research)) or “concurrent study” or “concurrent survey” or “concurrent analysis” or “incidence study” or “incidence survey” or “incidence analysis” or ((“follow-up” or followup) W/1 (stud* or survey or analysis)) or ((observation or observational) W/1 (study or survey or analysis)) or “clinical study” or “clinical trial” or “evaluation study” or “evaluation survey” or “evaluation analysis” or “quantitative study” or “quantitative analys*” or “numerical study” or “validation study” or “validation survey” or “validation analysis” or “quasi experimental study” or “quasi experimental analysis” or “quasiexperimental study” or “quasiexperimental analysis” or “field study” or “field survey” or “field analysis” or “in vivo study” or “in vivo analysis” or “panel study” or “panel survey” or “panel analysis” or ((prevention or preventive) W/3 (trial or study or analysis or survey)) or “replication study” or “replication analysis” or “replication trial” or “feasibility study” or “feasibility analysis” or “trend study” or “trend survey” or “trend analysis” or ((correlation* W/2 study) or (correlation* W/2 analys*)) or “case control study” or “case base study” or “case referrent study” or “case referent study” or “case referent study” or “case compeer study” or “case comparison study” or “matched case control” or “multicenter study” or “multi-center study” or “odds ratio” or “confidence interval” or (hazard* W/1 (model* or analys* or regression or ratio or ratios)) or “Cox model” or “Cox multivariate analyses” or “Cox multivariate analysis” or “Cox regression” or “Cox survival analyses” or “Cox survival analysis” or “Cox survival model” or “change analysis” or ((study or trial or random* or control*) and compar*))
4. PUBYEAR AFT 1994
5. 1 and 2 and 3 and 4
6. TITLE-ABS-KEY(newborn* or neonat* or infant* or toddler* or child* or adolescent* or paediatric* or pediatric* or girl or girls or boy or boys or teen or teens or teenager* or preschooler* or “pre-schooler*” or preteen or preteens or “pre-teen” or “pre-teens” or youth or youths) AND NOT TITLE-ABS-KEY(adult or adults or “middle age” or “middle aged” OR elderly OR geriatric* OR “old people” OR “old person*” OR “older people” OR “older person*” OR “very old”)
7. 5 and not 6
8. DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)
9. 7 and not 8
10. PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)
11. 9 and not 10

### National Guidelines Clearinghouse

(“Amyotrophic lateral sclerosis” or “Atrophic Muscular Disorder*” or Bronchiectasis or “Chronic Obstructive Pulmonary Disease*” or “congenital structual myopath*” or “Cystic Fibrosis” or hypercapnia or hypoventilation or “Interstitial Lung Disease*” or kyphosis or “Motor Neuron Disease*” or “Muscular Disease*” or Myositis or “Myotonic Disorder*” or “Neuromuscular Disease*” or Obesity or “obstructive lung disease*” or “Pulmonary fibrosis” or “respiratory failure” or “respiratory insufficiency” or scoliosis or “Spinal Cord Injur*” or “Spinal Muscular Atrophy” or “structural congenital myopath*”) AND (BiPAP OR BPAP OR CPAP OR “noninvasive positive pressure ventilation” OR “non-invasive positive pressure ventilation” OR “noninvasive ventilation” OR “non-invasive ventilation” OR NPPV OR “Positive Airway Pressure*” OR “positive end-expiratory pressure*”)

Limited to Adults

#### ClinicalTrials.gov

All limited to Adults

(“Amyotrophic lateral sclerosis” or “Atrophic Muscular Disorder*” or Bronchiectasis or “Chronic Obstructive Pulmonary Disease*” or “congenital structual myopath*” or “Cystic Fibrosis” or hypercapnia or hypoventilation or “Interstitial Lung Disease*”) AND (BiPAP or BPAP or CPAP or “noninvasive positive pressure ventilation” or “non-invasive positive pressure ventilation” or NPPV or “Positive Airway Pressure*” or “positive end-expiratory pressure*”) (kyphosis or “Motor Neuron Disease*” or “Muscular Disease*” or Myositis or “Myotonic Disorder*” or “Neuromuscular Disease*” or Obesity or “obstructive lung disease*” or “Pulmonary fibrosis” or “respiratory failure” or “respiratory insufficiency”) AND (BiPAP or BPAP or CPAP or “noninvasive positive pressure ventilation” or “non-invasive positive pressure ventilation” or NPPV or “Positive Airway Pressure*” or “positive end-expiratory pressure*”) (scoliosis or “Spinal Cord Injur*” or “Spinal Muscular Atrophy” or “structural congenital myopath*”) AND (BiPAP or BPAP or CPAP or “noninvasive positive pressure ventilation” or “non-invasive positive pressure ventilation” or NPPV or “Positive Airway Pressure*” or “positive end-expiratory pressure*”)

## Search Strategy 2

### Ovid

Database(s): Embase 1988 to 2018 Week 26, EBM Reviews - Cochrane Central Register of Controlled Trials May 2018, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to June 20, 2018, Ovid MEDLINE(R) Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) 1946 to Present

Search Strategy:

# | Searches
1 | exp Home Care Services/
2 | (((domestic or home or domiciliary) adj3 (residence or residences or setting or settings or care or nurs* or help or service* or treatment* or therap* or “respiratory care” or “respiratory treatment*” or “respiratory therap*” or “respiratory service*” or “respiratory assist*” or ventilat*)) or “assisted living” or homecare).ti,ab,hw,kw.
3 | “nursing home*”.ti,ab,hw,kw.
4 | (1 or 2) not 3
5 | exp Respiration, Artificial/
6 | (((facial or face or nasal) adj3 mask*) or ((respiration* or respiratory or breathing) adj3 (assist* or controlled or mechanical)) or “artificial respiration*” or BiPAP or CPAP or “Fluidic Breathing Assister” or HMV or IPPB or IPPV or NIAV or NIV or NPPV or “Oxygen Regulator*” or PAP or PAV or “Portable Oxygen” or “Positive Airway Pressure*” or “positive end-expiratory pressure*” or “positive pressure*” or respirator or respirators or “Respiratory insufficiency” or Tracheostom* or ventilation or ventilator*).ti,ab,hw,kw.
7 | 5 or 6
8 | 4 and 7
9 | limit 8 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) [Limit not valid in Embase,CCTR,CDSR; records were retained]
10 | limit 9 to (adult <18 to 64 years> or aged <65+ years>) [Limit not valid in CCTR,CDSR,Ovid MEDLINE(R),Ovid MEDLINE(R) Daily Update,Ovid MEDLINE(R) In-Process,Ovid MEDLINE(R) Publisher; records were retained]
11 | limit 8 to (“all infant (birth to 23 months)” or “all child (0 to 18 years)” or “newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)”) [Limit not valid in Embase,CCTR,CDSR; records were retained]
12 | limit 11 to (embryo or infant or child or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>) [Limit not valid in CCTR,CDSR,Ovid MEDLINE(R),Ovid MEDLINE(R) Daily Update,Ovid MEDLINE(R) In-Process,Ovid MEDLINE(R) Publisher; records were retained]
13 | 12 not 10
14 | 8 not 13
15 | exp Guideline/ or exp Practice Guideline/
16 | exp meta analysis/
17 | exp Meta-Analysis as Topic/
18 | exp “systematic review”/
19 | exp controlled study/
20 | exp Randomized Controlled Trial/
21 | exp triple blind procedure/
22 | exp Double-Blind Method/
23 | exp Single-Blind Method/
24 | exp latin square design/
25 | exp comparative study/
26 | exp Cohort Studies/
27 | exp longitudinal study/
28 | exp retrospective study/
29 | exp prospective study/
30 | exp population research/
31 | exp observational study/
32 | clinical study/
33 | exp Evaluation Studies/
34 | exp quantitative study/
35 | exp validation studies/
36 | exp quasi experimental study/
37 | exp field study/
38 | in vivo study/
39 | exp panel study/
40 | exp prevention study/
41 | exp replication study/
42 | exp Feasibility Studies/
43 | exp trend study/
44 | exp correlational study/
45 | exp case-control studies/
46 | exp confidence interval/
47 | exp regression analysis/
48 | exp proportional hazards model/
49 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or “consensus development” or guideline* or “position statement*” or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (random* adj1 allocat*) or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or multivariate or “comparative study” or “comparative survey” or “comparative analysis” or (intervention* adj2 study) or (intervention* adj2 trial) or crossover or “cross-over” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or (population adj3 (stud* or survey* or analys* or research)) or “concurrent study” or “concurrent survey” or “concurrent analysis” or “incidence study” or “incidence survey” or “incidence analysis” or ((“follow-up” or followup) adj (stud* or survey or analysis)) or ((observation or observational) adj (study or survey or analysis)) or “clinical study” or “clinical trial” or “evaluation study” or “evaluation survey” or “evaluation analysis” or “quantitative study” or “quantitative analys*” or “numerical study” or “validation study” or “validation survey” or “validation analysis” or “quasi experimental study” or “quasi experimental analysis” or “quasiexperimental study” or “quasiexperimental analysis” or “field study” or “field survey” or “field analysis” or “in vivo study” or “in vivo analysis” or “panel study” or “panel survey” or “panel analysis” or ((prevention or preventive) adj3 (trial or study or analysis or survey)) or “replication study” or “replication analysis” or “replication trial” or “feasibility study” or “feasibility analysis” or “trend study” or “trend survey” or “trend analysis” or ((correlation* adj2 study) or (correlation* adj2 analys*)) or “case control study” or “case base study” or “case referrent study” or “case referent study” or “case referent study” or “case compeer study” or “case comparison study” or “matched case control” or “multicenter study” or “multi-center study” or “odds ratio” or “confidence interval” or (hazard* adj (model* or analys* or regression or ratio or ratios)) or “Cox model” or “Cox multivariate analyses” or “Cox multivariate analysis” or “Cox regression” or “Cox survival analyses” or “Cox survival analysis” or “Cox survival model” or “change analysis” or ((study or trial or random* or control*) and compar*)).mp,pt.
50 | or/15-49
51 | 14 and 50
52 | limit 51 to (editorial or erratum or letter or note or addresses or autobiography or bibliography or biography or blogs or comment or dictionary or directory or interactive tutorial or interview or lectures or legal cases or legislation or news or newspaper article or overall or patient education handout or periodical index or portraits or published erratum or video-audio media or webcasts) [Limit not valid in Embase,CCTR,CDSR,Ovid MEDLINE(R),Ovid MEDLINE(R) Daily Update,Ovid MEDLINE(R) In-Process,Ovid MEDLINE(R) Publisher; records were retained]
53 | from 52 keep 45-48
54 | (51 not 52) or 53
55 | remove duplicates from 54

### Scopus

1. TITLE-ABS-KEY(((domestic or home or domiciliary) W/3 (residence or residences or setting or settings or care or nurs* or help or service* or treatment* or therap* or “respiratory care” or “respiratory treatment*” or “respiratory therap*” or “respiratory service*” or “respiratory assist*” or ventilat*)) OR “assisted living” OR homecare or HMV)
2. TITLE-ABS-KEY(((facial or face or nasal) W/3 mask*) OR ((respiration* or respiratory or breathing) W/3 (assist* or controlled or mechanical)) OR “artificial respiration*” OR BiPAP OR CPAP OR “Fluidic Breathing Assister” OR HMV OR IPPB OR IPPV OR NIAV OR NIV OR NPPV OR “Oxygen Regulator*” OR PAP OR PAV OR “Portable Oxygen” OR “Positive Airway Pressure*” OR “positive end-expiratory pressure*” OR “positive pressure*” OR respirator OR respirators OR “Respiratory insufficiency” OR Tracheostom* OR ventilation OR ventilator*)
3. TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or “consensus development” or guideline* or “position statement*” or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (random* W/1 allocat*) or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or multivariate or “comparative study” or “comparative survey” or “comparative analysis” or (intervention* W/2 study) or (intervention* W/2 trial) or crossover or “cross-over” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or (population W/3 (stud* or survey* or analys* or research)) or “concurrent study” or “concurrent survey” or “concurrent analysis” or “incidence study” or “incidence survey” or “incidence analysis” or ((“follow-up” or followup) W/1 (stud* or survey or analysis)) or ((observation or observational) W/1 (study or survey or analysis)) or “clinical study” or “clinical trial” or “evaluation study” or “evaluation survey” or “evaluation analysis” or “quantitative study” or “quantitative analys*” or “numerical study” or “validation study” or “validation survey” or “validation analysis” or “quasi experimental study” or “quasi experimental analysis” or “quasiexperimental study” or “quasiexperimental analysis” or “field study” or “field survey” or “field analysis” or “in vivo study” or “in vivo analysis” or “panel study” or “panel survey” or “panel analysis” or ((prevention or preventive) W/3 (trial or study or analysis or survey)) or “replication study” or “replication analysis” or “replication trial” or “feasibility study” or “feasibility analysis” or “trend study” or “trend survey” or “trend analysis” or ((correlation* W/2 study) or (correlation* W/2 analys*)) or “case control study” or “case base study” or “case referrent study” or “case referent study” or “case referent study” or “case compeer study” or “case comparison study” or “matched case control” or “multicenter study” or “multi-center study” or “odds ratio” or “confidence interval” or (hazard* W/1 (model* or analys* or regression or ratio or ratios)) or “Cox model” or “Cox multivariate analyses” or “Cox multivariate analysis” or “Cox regression” or “Cox survival analyses” or “Cox survival analysis” or “Cox survival model” or “change analysis” or ((study or trial or random* or control*) and compar*))
4. 1 and 2 and 3
5. TITLE-ABS-KEY(newborn* or neonat* or infant* or toddler* or child* or adolescent* or paediatric* or pediatric* or girl or girls or boy or boys or teen or teens or teenager* or preschooler* or “pre-schooler*” or preteen or preteens or “pre-teen” or “pre-teens” or youth or youths) AND NOT TITLE-ABS-KEY(adult or adults or “middle age” or “middle aged” OR elderly OR geriatric* OR “old people” OR “old person*” OR “older people” OR “older person*” OR “very old”)
6. 4 and not 5
7. DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)
8. 6 and not 7
9. PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)
10. 8 and not 9

#### National Guidelines Clearinghouse

((home OR domestic OR domiciliary or homecare or “assisted living” or HMV) AND (BiPAP OR CPAP OR “face mask*” OR “facial mask*” OR “Fluidic Breathing Assister” OR HMV OR IPPB OR IPPV OR “nasal mask*” OR NIAV OR NIV OR NPPV OR “Oxygen Regulator*” OR PAP OR PAV OR “Portable Oxygen” OR “Positive Airway Pressure*” OR “positive end-expiratory pressure*” OR “positive pressure*” OR respirat* OR Tracheostom* OR ventilat*)) NOT “nursing home*”

#### ClinicalTrials.gov

All limited to Adults

((domestic OR home OR domiciliary OR homecare OR “assisted living”) NOT “nursing home”) AND ((facial OR face OR nasal) AND mask*)

((domestic OR home OR domiciliary OR homecare OR “assisted living”) NOT “nursing home”) AND ((respiration* OR respiratory OR breathing) AND (assist* OR controlled OR mechanical))

((domestic OR home OR domiciliary OR homecare OR “assisted living”) NOT “nursing home”) AND (“artificial respiration*” OR BiPAP OR CPAP OR “Fluidic Breathing Assister” OR HMV OR IPPB)

((domestic OR home OR domiciliary OR homecare OR “assisted living”) NOT “nursing home”) AND (IPPV OR NIAV OR NIV OR NPPV OR “Oxygen Regulator*” OR PAP OR PAV OR “Portable Oxygen”)

((domestic OR home OR domiciliary OR homecare OR “assisted living”) NOT “nursing home”) AND (“Positive Airway Pressure*” OR “positive end-expiratory pressure*” OR “positive pressure*” OR respirator)

((domestic OR home OR domiciliary OR homecare OR “assisted living”) NOT “nursing home”) AND (respirators OR “Respiratory insufficiency” OR Tracheostom* OR ventilation OR ventilator*)