# Appendix A Flow Chart

Figure A.1 Flow chart