# References

1 Center for Behavioral Health Statistics and Quality. Results from the 2015 National Survey on Drug Use and Health: Detailed Tables. Rockville, MD: Substance Abuse and Mental Health Services Administration; 2016. http://www.samhsa.gov/data/sites/default/files/NSDUH-DetTabs-2015/NSDUHDetTabs-2015/NSDUH-DetTabs-2015.pdf. Accessed on September 23, 2016.
2 Kessler RC; Berglund P; Demler O; Jin R; Koretz D; Merikangas KR; Rush AJ; Walters EE; Wang PS. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. 2003 Jun 18;289(23):3095-105. PMID: 12813115.12813115
3 Wang PS; Lane M; Olfson M; Pincus HA; Wells KB; Kessler RC. Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005 Jun;62(6):629-40. PMID: 15939840.15939840
4 Trivedi MH; Rush AJ; Wisniewski SR; Nierenberg AA; Warden D; Ritz L; Norquist G; Howland RH; Lebowitz B; McGrath PJ; Shores-Wilson K; Biggs MM; Balasubramani GK; Fava M. Evaluation of outcomes with citalopram for depression using measurement-based care in STAR*D: implications for clinical practice. Am J Psychiatry. 2006 Jan;163(1):28-40. PMID: 16390886.16390886
5 Thase ME; Rush AJ. When at first you don’t succeed: sequential strategies for antidepressant nonresponders. J Clin Psychiatry. 1997;58 Suppl 13:23-9. PMID: 9402916.9402916
6 Berlim MT; Fleck MP; Turecki G. Current trends in the assessment and somatic treatment of resistant/refractory major depression: an overview. Ann Med. 2008;40(2):149-59. PMID: 18293145.18293145
7 Rush AJ; Trivedi MH; Wisniewski SR; Nierenberg AA; Stewart JW; Warden D; Niederehe G; Thase ME; Lavori PW; Lebowitz BD; McGrath PJ; Rosenbaum JF; Sackeim HA; Kupfer DJ; Luther J; Fava M. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: A STAR*D report. Am J Psychiatry. 2006 Nov;163(11):1905-17. doi: 10.1176/appi.ajp.163.11.1905. PMID: WOS:000241669900014.17074942
8 Perlis RH; Ostacher MJ; Patel JK; Marangell LB; Zhang H; Wisniewski SR; Ketter TA; Miklowitz DJ; Otto MW; Gyulai L; Reilly-Harrington NA; Nierenberg AA; Sachs GS; Thase ME. Predictors of recurrence in bipolar disorder: primary outcomes from the Systematic Treatment Enhancement Program for Bipolar Disorder (STEP-BD). Am J Psychiatry. 2006 Feb;163(2):217-24. doi: 10.1176/appi.ajp.163.2.217. PMID: 16449474.16449474
9 Gibson TB; Jing Y; Smith Carls G; Kim E; Bagalman JE; Burton WN; Tran QV; Pikalov A; Goetzel RZ. Cost burden of treatment resistance in patients with depression. Am J Manag Care. 2010 May;16(5):370-7. PMID: 20469957.20469957
10 Crown WH; Finkelstein S; Berndt ER; Ling D; Poret AW; Rush AJ; Russell JM. The impact of treatment-resistant depression on health care utilization and costs. J Clin Psychiatry. 2002 Nov;63(11):963-71. PMID: 12444808.12444808
11 Ivanova JI; Birnbaum HG; Kidolezi Y; Subramanian G; Khan SA; Stensland MD. Direct and indirect costs of employees with treatment-resistant and non-treatment-resistant major depressive disorder. Curr Med Res Opin. 2010 Oct;26(10):2475-84. doi: 10.1185/03007995.2010.517716. PMID: 20825269.20825269
12 Social Security Administration. SSI Annual Statistical Report, 2011. Washington, DC: Social Security Administration, Office of Retirement and Disability Policy, Office of Research, Evaluation, and Statistics; 2012. http://www.ssa.gov/policy/docs/statcomps/ssi_asr/2011/ssi_asr11.pdf (Table 6, P. 25). Accessed on 27 May, 2016.
13 Fiske A; Wetherell JL; Gatz M. Depression in older adults. Annu Rev Clin Psychol. 2009;5:363-89. doi: 10.1146/annurev.clinpsy.032408.153621. PMID: 19327033.19327033
14 Center for Medicare Advocacy. Medicare and Mental Health. Washington, DC: Center for Medicare Advocacy; n.d. http://www.medicareadvocacy.org/medicare-and-mental-health/. Accessed on 27 May, 2016.
15 Chesney E; Goodwin GM; Fazel S. Risks of all-cause and suicide mortality in mental disorders: a meta-review. World Psychiatry. 2014 Jun;13(2):153-60. doi: 10.1002/wps.20128. PMID: 24890068.24890068
16 National Heart, Lung, and Blood Institute. Who Is at Risk for Heart Disease? Bethesda, MD: National Institutes of Health; 2014. http://www.nhlbi.nih.gov/health/healthtopics/topics/hdw/atrisk. Accessed on 27 May, 2016.
17 Khawaja IS; Westermeyer JJ; Gajwani P; Feinstein RE. Depression and coronary artery disease: the association, mechanisms, and therapeutic implications. Psychiatry (Edgmont). 2009 Jan;6(1):38-51. PMID: 19724742.19724742
18 Trevino K; McClintock SM; McDonald Fischer N; Vora A; Husain MM. Defining treatment-resistant depression: a comprehensive review of the literature. Ann Clin Psychiatry. 2014 Aug;26(3):222-32. PMID: 25166485.25166485
19 Association AP. Practice Guideline for the Treatment of Patients With Major Depressive Disorder. Third ed. Washington, DC: American Psychiatric Association; 2010.
20 Lam RW; Kennedy SH; Grigoriadis S; McIntyre RS; Milev R; Ramasubbu R; Parikh SV; Patten SB; Ravindran AV; Canadian Network for M; Anxiety T. Canadian Network for Mood and Anxiety Treatments (CANMAT) clinical guidelines for the management of major depressive disorder in adults. III. Pharmacotherapy. J Affect Disord. 2009 Oct;117 Suppl 1:S26-43. doi: 10.1016/j.jad.2009.06.041. PMID: 19674794.19674794
21 Institute for Clinical Systems Improvement. Depression, Adult in Primary Care. Bloomington, MN Institute for Clinical Systems Improvement 2016. http://www.icsi.org/guidelines__more/catalog_guidelines_and_more/catalog_guidelines/catalog_behavioral_health_guidelines/depression. Accessed on 27 May, 2016.
22 National Institute for Health and Clinical Excellence (NICE). Depression. The treatment and management of depression in adults. Manchester, England: National Institute for Health and Clinical Excellence; 2004.
23 Department of Veterans Affairs; Department of Defense. VA/DoD Clinical Practice Guideline for the Management of Major Depressive Disorder. Washington, DC: Department of Veterans Affairs and Department of Defense; 2016. http://www.healthquality.va.gov/guidelines/MH/mdd/MDDFullFinal5192016.pdf. Accessed on 27 May, 2016.
24 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; January 2014. www.effectivehealthcare.ahrq.gov/methodsguide.cfm.
25 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. Fourth ed. Washington, DC: American Psychiatric Association; 1994.
26 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders (5th edition; DSM-5). Arlington, VA: American Psychiatric Association; 2013.
27 Higgins JP; Altman DG; Gotzsche PC; Juni P; Moher D; Oxman AD; Savovic J; Schulz KF; Weeks L; Sterne JA; Cochrane Bias Methods G; Cochrane Statistical Methods G. The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. doi: 10.1136/bmj.d5928. PMID: 22008217.22008217
28 Wells GA; Shea B; O’Connell D; Peterson J; Welch V; Losos M; Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses [webpage on the Internet]. Ottawa, ON: Ottawa Hospital Research Institute; 2011. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed on 5 February, 2013.
29 United Nations Development Programme. Human Development Report 2015: Work for Human Development. New York, NY: United Nations Development Programme; 2015. http://hdr.undp.org/sites/default/files/2015_human_development_report.pdf. Accessed on May 22, 2017.
30 Fava M; Davidson KG. Definition and epidemiology of treatment-resistant depression. Psychiatr Clin North Am. 1996 Jun;19(2):179-200. PMID: 8827185.8827185
31 Berlim MT; Turecki G. What is the meaning of treatment resistant/refractory major depression (TRD)? A systematic review of current randomized trials. Eur Neuropsychopharmacol. 2007 Nov;17(11):696-707. PMID: 17521891.17521891
32 Thomas SP; Nandhra HS; Jayaraman A. Systematic review of lamotrigine augmentation of treatment resistant unipolar depression (TRD). J Ment Health. 2010 Apr;19(2):168-75. doi: 10.3109/09638230903469269 [doi]. PMID: 20433324.20433324
33 Trivedi RB; Nieuwsma JA; Williams JW. Examination of the utility of psychotherapy for patients with treatment resistant depression: a systematic review (Structured abstract). J Gen Intern Med. 2011(6):643-50. PMID: DARE-12011004035.21184287
34 Silverstein WK; Noda Y; Barr MS; Vila-Rodriguez F; Rajji TK; Fitzgerald PB; Downar J; Mulsant BH; Vigod S; Daskalakis ZJ; Blumberger DM. Neurobiological predictors of response to dorsolateral prefrontal cortex repetitive transcranial magnetic stimulation in depression: a systematic review. Depress Anxiety. 2015:32(121:871-91. PMID: 26382227.26382227
35 Zhang YQ; Zhu D; Zhou XY; Liu YY; Qin B; Ren GP; Xie P. Bilateral repetitive transcranial magnetic stimulation for treatment-resistant depression: A systematic review and meta-analysis of randomized controlled trials. Braz J Med Biol Res. 2015:48(3): 198-206.25590350
36 De Carlo V; Calati R: Serretti A. Sociodemographic and clinical predictors of nonresponse/non-remission in treatment resistant depressed patients: A systematic review. Psychiatry Res. 2016:240:421-30. doi: 10.1016/j.psychres.2016.04.034. PMID: 2016-28410-067.27155594
37 Sackeim HA. The definition and meaning of treatment-resistant depression. J Clin Psychiatry. 2001:62 Suppl 16:10-7. PMID: 11480879.11480879
38 New England Comparative Effectiveness Public Advisory Council. Treatment Options for Treatment-Resistant Depression: Repetitive Transcranial Magnetic Stimulation. Boston, MA: Institute for Clinical and Economic Review; 2012. http://cepac.icer-review.org/wpcontent/uploads/2011/04/rTMS-CoveragePolicy-Analysis.pdf. Accessed on 31 May, 2016.
39 Edwards SJ; Hamilton V; Nherera L; Trevor N. Lithium or an atypical antipsychotic drug in the management of treatment-resistant depression: a systematic review and economic evaluation. Health Technol Assess. 2013 Nov;17(54):l-190. doi: 10.3310/htal7540 [doi], PMID: 24284258.24284258
40 Gaynes BN; Lloyd SW; Lux L; Gartlehner G; Hansen RA; Brode S; Jonas DE; Swinson Evans T; Viswanathan M; Lohr KN. Repetitive transcranial magnetic stimulation for treatment-resistant depression: a systematic review and meta-analysis. J Clin Psychiatry. 2014 May;75(5):477-89. doi: 10.4088/JCP.13r08815. PMID: 24922485.24922485
41 Washington State Health Care Authority. Nonpharmacologic Treatments for Treatment-Resistant Depression. 2014.
42 Malhi GS; Bassett D; Boyce P; Bryant R; Fitzgerald PB; Fritz K; Hopwood M; Lyndon B; Mulder R; Murray G; Porter R; Singh AB. Royal Australian and New Zealand College of Psychiatrists clinical practice guidelines for mood disorders. Aust N Z J Psychiatry. 2015 Dec;49(12):1087-206. 206. doi: 10.1177/0004867415617657. PMID: 26643054.26643054
43 Papadimitropoulou K; Vossen C; Karabis A; Donatti C; Kubitz N. Comparative Efficacy and Tolerability of Pharmacological and Somatic Interventions in Adult Patients with Treatment-Resistant Depression: A Systematic Review and Network Meta-analysis. Curr Med Res Opin. 2016 Dec 30:1-27. doi: 10.1080/03007995.2016.1277201. PMID: 28035869.28035869
44 Ruhe HG; van Rooijen G; Spijker J; Peeters FP; Schene AH. Staging methods for treatment resistant depression. A systematic review. J Affect Disord. 2012 Mar;137(1-3):35-45. doi: 10.1016/j.jad.2011.02.020. PMID: 21435727.21435727
45 Fava M. Diagnosis and definition of treatment-resistant depression. Biol Psychiatry. 2003;53(8):649-59.12706951
46 Fekadu A; Wooderson S; Donaldson C; Markopoulou K; Masterson B; Poon L; Cleare AJ. A multidimensional tool to quantify treatment resistance in depression: the Maudsley staging method. J Clin Psychiatry. 2009 Feb;70(2):177-84. PMID: 19192471.19192471
47 European Medicines Agency. Guideline on clinical investigation of medicinal products in the treatment of depression. London: European Medicines Agency; 2013. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2013/05/WC500143770.pdf. Accessed on January 8, 2018.
48 Boutron I; Altman DG; Moher D; Schulz KF; Ravaud P; Group CN. CONSORT Statement for Randomized Trials of Nonpharmacologic Treatments: A 2017 Update and a CONSORT Extension for Nonpharmacologic Trial Abstracts. Ann Intern Med. 2017 Jul 04;167(1):40-7. doi: 10.7326/M17-0046. PMID: 28630973.28630973
49 von Elm E; Altman DG; Egger M; Pocock SJ; Gotzsche PC; Vandenbroucke JP; Initiative S. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. 2008 Apr;61(4):344-9. doi: 10.1016/j.jclinepi.2007.11.008. PMID: 18313558.18313558
50 Naumann J; Grebe J; Kaifel S; Weinert T; Sadaghiani C; Huber R. Effects of hyperthermic baths on depression, sleep and heart rate variability in patients with depressive disorder: a randomized clinical pilot trial. BMC Complement Altern Med. 2017 Mar 28;17(1):172. doi: 10.1186/s12906-017-1676-5. PMID: 28351399.28351399
51 Aaronson ST; Sears P; Ruvuna F; Bunker M; Conway CR; Dougherty DD; Reimherr FW; Schwartz TL; Zajecka JM. A 5-year observational study of patients with treatment-resistant depression treated with vagus nerve stimulation or treatment as usual: comparison of response, remission, and suicidality. Am J Psychiatry. 2017 Jul 01;174(7):640-8. doi: 10.1176/appi.ajp.2017.16010034. PMID: 28359201.28359201
52 NeuroStar Advanced Therapy. About NeuroStar® TMS Therapy. Malvern, PA: NeuroStar Advanced Therapy; 2017. https://neurostar.com/neurostar-tmsdepression-treatment/. Accessed on August 2, 2017.
53 Singh J; Singh A; Kar SK; Pahuja E. Early augmentation response with low-frequency repetitive transcranial magnetic stimulation in treatment resistant depression. Clinical Psychopharmacology and Neuroscience. 2017;15(2):197-8. doi: 10.9758/cpn.2017.15.2.197. PMID: 2017-25469-017.28449572
54 Kessler RC; Chiu WT; Demler O; Merikangas KR; Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005 Jun;62(6):617-27. doi: 10.1001/archpsyc.62.6.617. PMID: 15939839.15939839
55 Russell JM; Hawkins K; Ozminkowski RJ; Orsini L; Crown WH; Kennedy S; Finkelstein S; Berndt E; Rush AJ. The cost consequences of treatment-resistant depression. J Clin Psychiatry. 2004 Mar;65(3):341-7. PMID: 15096073.15096073
56 National Institute for Health and Clinical Excellence (NICE). Depression. The treatment and management of depression in adults. Manchester, England: National Institute for Health and Clinical Excellence; 2004.
57 Centers for Medicare & Medicaid Services. MEDCAC Meeting 4/27/2016 - Treatment Resistant Depression. Baltimore, MD: Centers for Medicare & Medicaid Services; 2016. https://www.cms.gov/medicarecoverage-database/details/medcac-meetingdetails.aspx?MEDCACId=71&bc=AAAIAAAAAAAAAA%3d%3d&. Accessed 21 November 2016.
58 Gaynes BN; Lux L; Lloyd S; Hansen RA; Gartlehner G; Thieda P; Jonas D; Brode S; Swinson Evans T; Crotty K; Viswanathan M; KN L. Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults Comparative Effectiveness Review No. 33. (Prepared by RTI International-University of North Carolina under Contract No. 290-02-0016I, TO #2.) AHRQ Publication No. 11-EHC056-EF. Rockville, MD: Agency for Healthcare Research and Quality; Sep 2011. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm. PMID: 2209147222091472.
59 Gartlehner G; Gaynes B; Amick H; Asher G; Morgan LC; Coker-Schwimmer E; Forneris C; Boland E; Lux L; Gaylord S; Bann C; Pierl CB; Lohr K. Nonpharmacological Versus Pharmacological Treatments for Adult Patients with Major Depressive Disorder Comparative Effectiveness Review No. 161. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2012-00008I.) AHRQ Publication No. 15(16)-EHC031-EF. Rockville, MD: Agency for Healthcare Research and Quality; December 2015. www.effectivehealthcare.ahrq.gov/reports/final.cfm. PMID: 2676443826764438.
60 Guyatt GH; Oxman AD; Kunz R; Atkins D; Brozek J; Vist G; Alderson P; Glasziou P; Falck-Ytter Y; Schunemann HJ. GRADE guidelines: 2. Framing the question and deciding on important outcomes. J Clin Epidemiol. 2011 Apr;64(4):395-400. doi: 10.1016/j.jclinepi.2010.09.012. PMID: 21194891.21194891
61 U.S. Federal Drug Administration. CFR Code of Federal Regulations Title 21 Section 312.32 IND Safety Reporting. Silver Spring, MD: U.S. Federal Drug Administration; 2016. https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCFR/CFRSearch.cfm?fr=312.32. Accessed 21 November 2016.
62 U.S. Federal Drug Administration. Summary of Safety and Effectiveness Data. Silver Spring, MD: U.S. Food and Drug Administration; 2005. www.accessdata.fda.gov/cdrh_docs/pdf/P970003S050b.pdf. Accessed on March 20, 2017.
63 Fu R; Gartlehner G; Grant M; Shamliyan T; Sedrakyan A; Wilt TJ; Griffith L; Oremus M; Raina P; Ismaila A; Santaguida P; Lau J; Trikalinos TA. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Methods Guide for Effectiveness and Comparative Effectiveness Reviews [Internet]. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
64 Repetitive transcranial magnetic stimulation for treatment-resistant depression: A systematic review and meta-analysis of randomized controlled trials. Ontario Health Technology Assessment Series. 2016;16(5):1-66.
65 Papadimitropoulou K; Vossen C; Karabis A; Donatti C; Kubitz N. Comparative efficacy and tolerability of pharmacological and somatic interventions in adult patients with treatment-resistant depression: a systematic review and network meta-analysis. Curr Med Res Opin. 2017;33(4):701-11. doi: 10.1080/03007995.2016.1277201.28035869
66 Luan S; Wan H; Wang S; Li H; Zhang B. Efficacy and safety of olanzapine/fluoxetine combination in the treatment of treatmentresistant depression: A meta-analysis of randomized controlled trials. Neuropsychiatr Dis Treat. 2017;13((Luan S.; Wan H.; Wang S.) Department of Mental Health, China-Japan Union Hospital of Jilin University, Changchun, China):609-20. doi: 10.2147/ndt.s127453.
67 Bauer M; Whybrow PC; Angst J; Versiani M; Moller HJ. World Federation of Societies of Biological Psychiatry (WFSBP) Guidelines for Biological Treatment of Unipolar Depressive Disorders, Part 1: Acute and continuation treatment of major depressive disorder. World J Biol Psychiatry. 2002 Jan;3(1):5-43. PMID: 12479086.12479086
68 Rossi S; Hallett M; Rossini PM; Pascual-Leone A. Safety, ethical considerations, and application guidelines for the use of transcranial magnetic stimulation in clinical practice and research. Clin Neurophysiol. 2009 Dec;120(12):2008-39. ; 10.1016/j.clinph.2009.08.016 [doi]. PMID: 19833552.19833552
69 Schlaepfer TE; Ågren H; Monteleone P; Gasto C; Pitchot W; Rouillon F; Nutt DJ; Kasper S. The hidden third: Improving outcome in treatment-resistant depression. Journal of Psychopharmacology. 2012;26(5):587-602.22236505
70 Harter M; Klesse C; Bermejo I; Schneider F; Berger M. Unipolar depression: diagnostic and therapeutic recommendations from the current S3/National Clinical Practice Guideline. Dtsch Arztebl Int. 2010 Oct;107(40):700-8. doi: 10.3238/arztebl.2010.0700. PMID: 21031129.21031129
71 National Institute for Health and Care Excellence. Repetititve transcranial magnetic stimulation for depression [Clinical Gudelines]. London: National Institute for Health and Care Excellence; 2015. http://nice.org.uk/guidance/ipg542 (http://nice.org.uk/guidance/ipg542.--).-- Accessed on May 22, 2017.
72 National Institute for Health and Clinical Excellence (NICE). Depression. The treatment and management of depression in adults. 2010(Revised October 2009).
73 National Institute for Health and Care Excellence. Vagus nerve stimulation for treatment-resistant depression. London: National Institute for Health and Care Excellence; 2009. http://nice.org.uk/guidance/ipg330 (http://nice.org.uk/guidance/ipg330.--).-- Accessed on May 22, 2017.
74 Kennedy SH; Lam RW; McIntyre RS; Tourjman SV; Bhat V; Blier P; Hasnain M; Jollant F; Levitt AJ; MacQueen GM; McInerney SJ; McIntosh D; Milev RV; Muller DJ; Parikh SV; Pearson NL; Ravindran AV; Uher R; Group CDW. Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Section 3. Pharmacological Treatments. Can J Psychiatry. 2016 Sep;61(9):540-60. doi: 10.1177/0706743716659417. PMID: 27486148.27486148
75 Parikh SV; Quilty LC; Ravitz P; Rosenbluth M; Pavlova B; Grigoriadis S; Velyvis V; Kennedy SH; Lam RW; MacQueen GM; Milev RV; Ravindran AV; Uher R; Canmat Depression Work Group. Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Section 2. Psychological Treatments. Can J Psychiatry. 2016 Sep;61(9):524-39. doi: 10.1177/0706743716659418. PMID: 27486150.27486150
76 Milev RV; Giacobbe P; Kennedy SH; Blumberger DM; Daskalakis ZJ; Downar J; Modirrousta M; Patry S; Vila-Rodriguez F; Lam RW; MacQueen GM; Parikh SV; Ravindran AV; Group CDW. Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Section 4. Neurostimulation Treatments. Can J Psychiatry. 2016 Sep;61(9):561-75. doi: 10.1177/0706743716660033. PMID: 27486154.27486154
77 Ravindran AV; Balneaves LG; Faulkner G; Ortiz A; McIntosh D; Morehouse RL; Ravindran L; Yatham LN; Kennedy SH; Lam RW; MacQueen GM; Milev RV; Parikh SV; Canmat Depression Work Group. Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Section 5. Complementary and Alternative Medicine Treatments. Can J Psychiatry. 2016 Sep;61(9):576-87. doi: 10.1177/0706743716660290. PMID: 27486153.27486153
78 MacQueen GM; Frey BN; Ismail Z; Jaworska N; Steiner M; Lieshout RJ; Kennedy SH; Lam RW; Milev RV; Parikh SV; Ravindran AV; Group CDW. Canadian Network for Mood and Anxiety Treatments (CANMAT) 2016 Clinical Guidelines for the Management of Adults with Major Depressive Disorder: Section 6. Special Populations: Youth, Women, and the Elderly. Can J Psychiatry. 2016 Sep;61(9):588-603. doi: 10.1177/0706743716659276. PMID: 27486149.27486149
79 Cleare A; Pariante CM; Young AH; Anderson IM; Christmas D; Cowen PJ; Dickens C; Ferrier IN; Geddes J; Gilbody S; Haddad PM; Katona C; Lewis G; Malizia A; McAllister-Williams RH; Ramchandani P; Scott J; Taylor D; Uher R; Members of the Consensus M. Evidence-based guidelines for treating depressive disorders with antidepressants: A revision of the 2008 British Association for Psychopharmacology guidelines. J Psychopharmacol. 2015 May;29(5):459-525. doi: 10.1177/0269881115581093. PMID: 25969470.25969470
80 Oquendo MA; Baca-Garcia E; Kartachov A; Khait V; Campbell CE; Richards M; Sackeim HA; Prudic J; Mann JJ. A computer algorithm for calculating the adequacy of antidepressant treatment in unipolar and bipolar depression. J Clin Psychiatry. 2003 Jul;64(7):825-33. PMID: 12934985.12934985
81 Souery D; Amsterdam J; de Montigny C; Lecrubier Y; Montgomery S; Lipp O; Racagni G; Zohar J; Mendlewicz J. Treatment resistant depression: methodological overview and operational criteria. Eur Neuropsychopharmacol. 1999 Jan;9(1-2):83-91. PMID: 10082232.10082232
82 Petersen T; Papakostas GI; Posternak MA; Kant A; Guyker WM; Iosifescu DV; Yeung AS; Nierenberg AA; Fava M. Empirical testing of two models for staging antidepressant treatment resistance. J Clin Psychopharmacol. 2005 Aug;25(4):336-41. . PMID: 16012276.16012276
83 McClintock SM; Cullum M; Husain MM; Rush AJ; Knapp RG; Mueller M; Petrides G; Sampson S; Kellner CH. Evaluation of the Effects od Severe Depression on Global Cognitive Function and Memory. CNS Spectr. 2010 May;15(5):304-13. PMID: 20448521.20448521
84 Smarr KL; Keefer AL. Measures of depression and depressive symptoms: Beck Depression Inventory-II (BDI-II), Center for Epidemiologic Studies Depression Scale (CES-D), Geriatric Depression Scale (GDS), Hospital Anxiety and Depression Scale (HADS), and Patient Health Questionnaire-9 (PHQ-9). Arthritis Care Res. 2011 Nov;63(S11):S454-66. doi: 10.1002/acr.20556. PMID: 22588766.22588766
85 Wang Y; Gorenstein C. Psychometric properties of the Beck Depression Inventory-II: a comprehensive review. Revista Brasileira de Psiquiatria. 2013;35:416-31.24402217
86 Hiroe T; Kojima M; Yamamoto I; Nojima S; Kinoshita Y; Hashimoto N; Watanabe N; Maeda T; Furukawa TA. Gradations of clinical severity and sensitivity to change assessed with the Beck Depression Inventory-II in Japanese patients with depression. Psychiatry Res. 2005 Jun 30;135(3):229-35. doi: 10.1016/j.psychres.2004.03.014. PMID: 15996749.15996749
87 Beck AT; Steer RA; Garbin MG. Psychometric properties of the Beck Depression Inventory: twenty-five years of evaluation. Clin Psychol Rev. 1988;8(1):77-100.
88 Dworkin RH; Turk DC; Wyrwich KW; Beaton D; Cleeland CS; Farrar JT; Haythornthwaite JA; Jensen MP; Kerns RD; Ader DN; Brandenburg N; Burke LB; Cella D; Chandler J; Cowan P; Dimitrova R; Dionne R; Hertz S; Jadad AR; Katz NP; Kehlet H; Kramer LD; Manning DC; McCormick C; McDermott MP; McQuay HJ; Patel S; Porter L; Quessy S; Rappaport BA; Rauschkolb C; Revicki DA; Rothman M; Schmader KE; Stacey BR; Stauffer JW; von Stein T; White RE; Witter J; Zavisic S. Interpreting the clinical importance of treatment outcomes in chronic pain clinical trials: IMMPACT recommendations. J Pain. 2008 Feb;9(2):105-21. doi: 10.1016/j.jpain.2007.09.005. PMID: 18055266.18055266
89 National Institute for Health and Care Excellence. Depression in adults. London: National Institute for Health and Care Excellence; 2011. https://www.nice.org.uk/guidance/qs8/chapter/quality-statement-1-assessment. Accessed on July 11, 2017.
90 Svanborg P; Asberg M. A comparison between the Beck Depression Inventory (BDI) and the self-rating version of the Montgomery Asberg Depression Rating Scale (MADRS). J Affect Disord. 2001 May;64(2-3):203-16. doi: Doi 10.1016/S0165-0327(00)00242-1. PMID: WOS:000168604400010.11313087
91 Lewinsohn PM; Seeley JR; Roberts RE; Allen NB. Center for Epidemiological Studies-Depression Scale (CES-D) as a screening instrument for depression among community-residing older adults. Psychol Aging. 1997;12:277-287.9189988
92 Haringsma R; Engels GI; Beekman AT; Spinhoven P. The criterion validity of the Center for Epidemiological Studies Depression Scale (CES-D) in a sample of self-referred elders with depressive symptomatology. Int J Geriatr Psychiatry. 2004 Jun;19(6):558-63. doi: 10.1002/gps.1130. PMID: 15211536.15211536
93 Orme JG; Reis J; Herz EJ. Factorial and discriminant validity of the Center for Epidemiological Studies Depression (CES-D) scale. J Clin Psychol. 1986 Jan;42(1):28-33. PMID: 3950011.3950011
94 Masson SC; Tejani AM. Minimum clinically important differences identified for commonly used depression rating scales. J Clin Epidemiol. 2013 Jul;66(7):805-7. doi: 10.1016/j.jclinepi.2013.01.010. PMID: WOS:000320426800018.23618794
95 Brink TL; Yesavage JA; Lum O; Heersema P; Adey MB; Rose TL. Screening tests for geriatric depression. Clin Gerontol. 1982;1:37-44.
96 Marcus RN; McQuade RD; Carson WH; Hennicken D; Fava M; Simon JS; Trivedi MH; Thase ME; Berman RM. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder: a second multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. 2008 Apr;28(2):156-65. doi: 10.1097/JCP.0b013e31816774f9. PMID: 18344725.18344725
97 Cullum S; Tucker S; Todd C; Brayne C. Screening for depression in older medical inpatients. Int J Geriatr Psychiatry. 2006 May;21(5):469-76. doi: 10.1002/gps.1497. PMID: 16676293.16676293
98 Bijl D; van Marwijk HW; Ader HJ; Beekman AT; de Haan M. Test-characteristics of the GDS-15 in screening for major depression in elderly patients in clinical practice. Clin Gerontol. 2005;29:1-9. doi: 10.1300/J018v29n01_01
99 Weintraub D; Oehlberg KA; Katz IR; Stern MB. Test characteristics of the 15-item geriatric depression scale and Hamilton depression rating scale in Parkinson disease. Am J Geriatr Psychiatry. 2006 Feb;14(2):169-75. doi: 10.1097/01.JGP.0000192488.66049.4b. PMID: 16473982.16473982
100 Friedman B; Heisel MJ; Delavan RL. Psychometric properties of the 15-item geriatric depression scale in functionally impaired, cognitively intact, community-dwelling elderly primary care patients. J Am Geriatr Soc. 2005 Sep;53(9):1570-6. doi: 10.1111/j.1532-5415.2005.53461.x. PMID: 16137289.16137289
101 Yesavage JA; Brink TL; Rose TL; Lum O; Huang V; Adey M; Leirer VO. Development and validation of a geriatric depression screening scale - a preliminary-report. J Psychiatr Res. 1983;17(1):37-49. doi: 10.1016/0022-3956(82)90033-4. PMID: WOS:A1983QQ74400004.
102 van Marwijk HW; Wallace P; de Bock GH; Hermans J; Kaptein AA; Mulder JD. Evaluation of the feasibility, reliability and diagnostic value of shortened versions of the geriatric depression scale. Br J Gen Pract. 1995 Apr;45(393):195-9. PMID: 7612321.7612321
103 Lopez MN; Quan NM; Carvajal PM. A psychometric study of the Geriatric Depression Scale. Eur J Psychol Assess. 2010;26(1):55-60. doi: 10.1027/1015-5759/a000008. PMID: WOS:000274049400008.
104 Mitchell AJ; Bird V; Rizzo M; Meader N. Diagnostic validity and added value of the geriatric depression scale for depression in primary care: a meta-analysis of GDS(30) and GDS(15). J Affect Disord. 2010 Sep;125(1-3):10-7. doi: 10.1016/j.jad.2009.08.019. PMID: WOS:000281377100002.19800132
105 Cusin C; Yang H; Yeung A; Fava M. Chapter 2. Rating scales for depression. In: Baer L, Blais MA, eds. Handbook of Clinical Rating Scales and Assessment in Psychiatry and Mental Health. Current Clinical Psychology. New York: Humana Press; 2010.
106 American Thoracic Society (ATS). Hamilton Rating Scale for Depression (HRSD). New York, NY: American Thoracic Society; 2013. http://www.thoracic.org/assemblies/srn/questionaires/hrsd.php. Accessed on July 3, 2017.
107 Price RB; Shungu DC; Mao X; Nestadt P; Kelly C; Collins KA; Murrough JW; Charney DS; Mathew SJ. Amino acid neurotransmitters assessed by proton magnetic resonance spectroscopy: relationship to treatment resistance in major depressive disorder. Biol Psychiatry. 2009 May 1;65(9):792-800. doi: 10.1016/j.biopsych.2008.10.025. PMID: 19058788.19058788
108 Bagby RM; Ryder AG; Schuller DR; Marshall MB. The Hamilton Depression Rating Scale: has the gold standard become a lead weight? Am J Psychiatry. 2004 Dec;161(12):2163-77. doi: 10.1176/appi.ajp.161.12.2163. PMID: 15569884.15569884
109 Lopez-Pina JA; Sanchez-Meca J; Rosa-Alcazar AI. The Hamilton Rating Scale for Depression: a meta-analytic reliability generalization study. Int J Clin Health Psychol. 2009 Jan;9(1):143-59. PMID: WOS:000262363900010.
110 Rush AJ; Trivedi MH; Ibrahim HM; Carmody TJ; Arnow B; Klein DN; Markowitz JC; Ninan PT; Kornstein S; Manber R; Thase ME; Kocsis JH; Keller MB. The 16-Item Quick Inventory of Depressive Symptomatology (QIDS), clinician rating (QIDS-C), and self-report (QIDS-SR): a psychometric evaluation in patients with chronic major depression. Biol Psychiatry. 2003 Sep 01;54(5):573-83. PMID: 12946886.12946886
111 Williams JBW. Standardizing the Hamilton Depression Rating Scale: past, present, and future. Eur Arch Psychiatry Clin Neurosci. 2001;251(S2):6-12. doi: 10.1007/bf03035120.11315519
112 Duru G; Fantino B. The clinical relevance of changes in the Montgomery-Asberg Depression Rating Scale using the minimum clinically important difference approach. Curr Med Res Opin. 2008 May;24(5):1329-35. doi: 10.1185/030079908X291958. PMID: 18377706.18377706
113 Carmody TJ; Rush AJ; Bernstein I; Warden D; Brannan S; Burnham D; Woo A; Trivedi MH. The Montgomery Asberg and the Hamilton ratings of depression: a comparison of measures. Eur Neuropsychopharmacol. 2006 Dec;16(8):601-11. doi: 10.1016/j.euroneuro.2006.04.008. PMID: 16769204.16769204
114 Substance Abuse and Mental Health Services Administration. Patient Health Quesionnaire (PHQ-9) Rockville, MD: SAMHSA; 2005. https://www.integration.samhsa.gov/images/res/PHQ%20-%20Questions.pdf. Accessed on May 21, 2017.
115 Maurer DM. Screening for depression. Am Fam Physician. 2012 Jan 15;85(2):139-44. PMID: 22335214.22335214
116 Spitzer RL; Kroenke K; Williams JB. Validation and utility of a self-report version of PRIME-MD: the PHQ primary care study. Primary Care Evaluation of Mental Disorders. Patient Health Questionnaire. JAMA. 1999 Nov 10;282(18):1737-44. PMID: 10568646.10568646
117 Kroenke K; Spitzer RL; Williams JB. The PHQ-9: validity of a brief depression severity measure. J Gen Intern Med. 2001 Sep;16(9):606-13. PMID: 11556941.11556941
118 Lowe B; Unutzer J; Callahan CM; Perkins AJ; Kroenke K. Monitoring depression treatment outcomes with the patient health questionnaire-9. Med Care. 2004 Dec;42(12):1194-201. PMID: 15550799.15550799
119 Lamoureux BE; Linardatos E; Fresco DM; Bartko D; Logue E; Milo L. Using the QIDS-SR16 to identify major depressive disorder in primary care medical patients. Behav Ther. 2010 Sep;41(3):423-31. PMID: WOS:000278892500015.20569790
120 Reilly TJ; MacGillivray SA; Reid IC; Cameron IM. Psychometric properties of the 16-item Quick Inventory of Depressive Symptomatology: a systematic review and meta-analysis. J Psychiatr Res. 2015 Jan;60:132-40. doi: 10.1016/j.jpsychires.2014.09.008. PMID: 25300442.25300442
121 Rush AJ; Pincus HA; First MB; Blacker D; Endicott J; Keith SJ; Phillips KA; Ryan ND; Smither J, G. R.; Tsuang MT; Widiger TA; Zarin DA. Handbook of Psychiatric Measures. Washington, DC: American Psychiatric Association; 2000.
122 Leucht S; Kane JM; Kissling W; Hamann J; Etschel E; Engel R. Clinical implications of Brief Psychiatric Rating Scale scores. Br J Psychiatry. 2005 Oct;187:366-71. doi: 10.1192/bjp.187.4.366. PMID: 16199797.16199797
123 Guy W. Clinical Global Impressions (CGI) scale. In: Rush AJ, Pincus HA, First MB, Blacker D, Endicott J, Keith SJ, ., eds. Handbook of psychiatric measures. 1st ed. Washington, DC: American Psychiatric Association; 2000:100-2.
124 Luciano JV; Ayuso-Mateos JL; Fernandez A; Serrano-Blanco A; Roca M; Haro JM. Psychometric properties of the twelve item World Health Organization Disability Assessment Schedule II (WHO-DAS II) in Spanish primary care patients with a first major depressive episode. J Affect Disord. 2010 Feb;121(1-2):52-8. doi: 10.1016/j.jad.2009.05.008. PMID: 19464735.19464735
125 Hermes ED; Sokoloff D; Stroup TS; Rosenheck RA. Minimum clinically important difference in the Positive and Negative Syndrome Scale with data from the Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE). J Clin Psychiatry. 2012 Apr;73(4):526-32. doi: 10.4088/JCP.11m07162. PMID: 22579152.22579152
126 Moncrieff J; Kirsch I. Empirically derived criteria cast doubt on the clinical significance of antidepressant-placebo differences. Contemp Clin Trials. 2015 Jul;43:60-2. doi: 10.1016/j.cct.2015.05.005. PMID: 25979317.25979317
127 Button KS; Kounali D; Thomas L; Wiles NJ; Peters TJ; Welton NJ; Ades AE; Lewis G. Minimal clinically important difference on the Beck Depression Inventory--II according to the patient’s perspective. Psychol Med. 2015 Nov;45(15):3269-79. doi: 10.1017/S0033291715001270. PMID: 26165748.26165748
128 Sheehan KH; Sheehan DV. Assessing treatment effects in clinical trials with the discan metric of the Sheehan Disability Scale. Int Clin Psychopharmacol. 2008 Mar;23(2):70-83. doi: 10.1097/YIC.0b013e3282f2b4d6. PMID: 18301121.18301121
129 Endicott J; Paulsson B; Gustafsson U; Schioler H; Hassan M. Quetiapine monotherapy in the treatment of depressive episodes of bipolar I and II disorder: Improvements in quality of life and quality of sleep. J Affect Disord. 2008 Dec;111(2-3):306-19. doi: 10.1016/j.jad.2008.06.019. PMID: 18774180.18774180
130 Holtzheimer PE; Kelley ME; Gross RE; Filkowski MM; Garlow SJ; Barrocas A; Wint D; Craighead MC; Kozarsky J; Chismar R; Moreines JL; Mewes K; Posse PR; Gutman DA; Mayberg HS. Subcallosal cingulate deep brain stimulation for treatment-resistant unipolar and bipolar depression. Arch Gen Psychiatry. 2012 Feb;69(2):150-8. doi: 10.1001/archgenpsychiatry.2011.1456. PMID: 22213770.22213770
131 Aas IH. Global Assessment of Functioning (GAF): properties and frontier of current knowledge. Ann Gen Psychiatry. 2010 May 07;9:20. doi: 10.1186/1744-859X-9-20. PMID: 20459646.20459646
132 Jones SH; Thornicroft G; Coffey M; Dunn G. A brief mental health outcome scale-reliability and validity of the Global Assessment of Functioning (GAF). Br J Psychiatry. 1995 May;166(5):654-9. PMID: 7620753.7620753
133 Lam RW; Michalak EE; Swinson RP. Assessment scales in depression, mania and anxiety. London: Taylor and Francis; 2005.
134 Endicott J; Nee J; Harrison W; Blumenthal R. Quality of Life Enjoyment and Satisfaction Questionnaire: a new measure. Psychopharmacol Bull. 1993;29(2):321-6. PMID: 8290681.8290681
135 Stevanovic D. Quality of Life Enjoyment and Satisfaction Questionnaire-short form for quality of life assessments in clinical practice: a psychometric study. J Psychiatr Ment Health Nurs. 2011 Oct;18(8):744-50. doi: 10.1111/j.1365-2850.2011.01735.x. PMID: 21896118.21896118
136 Demyttenaere K; Andersen HF; Reines EH. Impact of escitalopram treatment on Quality of Life Enjoyment and Satisfaction Quesionnaire scores in major depressive disorder and generalized anxiety disorder. Int Clin Psychopharmacol. 2008;23:276-86.18703937
137 Sheehan DV; Harnett-Sheehan K; Raj BA. The measurement of disability. Int Clin Psychopharmacol. 1996 Jun;11(Suppl 3):89-95. PMID: 8923116.8923116
138 Optum, Inc. SF-36 Health Survey. Eden Prairie, MN: Optum Inc; n.d. https://campaign.optum.com/content/optum/en/optum-outcomes/what-we-do/healthsurveys/sf-36v2-health-survey.html. Accessed on December 4, 2016.
139 Savovic J; Jones HE; Altman DG; Harris RJ; Juni P; Pildal J; Als-Nielsen B; Balk EM; Gluud C; Gluud LL; Ioannidis JP; Schulz KF; Beynon R; Welton NJ; Wood L; Moher D; Deeks JJ; Sterne JA. Influence of reported study design characteristics on intervention effect estimates from randomized, controlled trials. Ann Intern Med. 2012 Sep 18;157(6):429-38. doi: 10.7326/0003-4819-157-6-201209180-00537. PMID: 22945832.22945832
140 Lundh A; Sismondo S; Lexchin J; Busuioc OA; Bero L. Industry sponsorship and research outcome. Cochrane Database Syst Rev. 2012 Dec 12;12:MR000033. doi: 10.1002/14651858.MR000033.pub2. PMID: 23235689.23235689
141 Quiroz JA; Singh J; Gould TD; Denicoff KD; Zarate CA; Manji HK. Emerging experimental therapeutics for bipolar disorder: clues from the molecular pathophysiology. Mol Psychiatry. 2004 Aug;9(8):756-76. doi: 10.1038/sj.mp.4001521. PMID: 15136795.15136795