# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions. From the Agency for Healthcare Research and Quality: Aysegul Gozu, M.D., M.P.H., our task order officer, and Elise Berliner, Ph.D., director of the Technology Assessment Program at the Center for Evidence and Practice Improvement. From the Center for Medicare & Medicaid Services’ Coverage and Analysis Group: Susan M. Miller, M.D.; Rosemarie Hakim, Ph.D.; Linda Gousis, J.D.; and Lori Ashby, M.A., director of the Division of Medical and Surgical Services. From the RTI International—University of North Carolina Evidence-based Practice Center (EPC) staff: Carol Woodell, B.S.P.H., EPC project manager; Rachel Palmieri Weber, Ph.D., EPC project manager; Meera Viswanathan, Ph.D., EPC project director; Dan Jonas, M.D., M.P.H., EPC codirector; Lynn Whitener, Dr.P.H., M.S.L.S., librarian; Sharon Barrell, M.A., editor; and Loraine Monroe, publications specialist.