# Discussion

This chapter brings together the two parts of this Technology Assessment on treatment-resistant depression (TRD)—the Narrative Review Key Questions (KQs) 1 through 5 and the Systematic Review KQs 6 through 11. Findings for the former draw on (a) literature searches (one of which was systematic) of appropriate databases and (b) gray literature and materials such as various clinical practice guidelines, consensus statements, and other information found on three main websites. For these former topics, we drew on a total of 38 publications, of which 14 were systematic reviews, 6 were non-systematic reviews, and 18 were guidelines or consensus statement.

Findings for the latter represent syntheses that follow systematic literature searches in accord with standard methods for the Evidence-based Practice Center program of the Agency for Healthcare Research and Quality. For these latter topics, we drew on a total of 163 studies (in 197 publications), of which 143 were randomized controlled trials (RCTs) of various designs, 4 were nonrandomized trials, 13 were observational studies, 2 were case controls and 1 was an interrupted time series.

A core theme throughout our syntheses is the degree to which clinicians, researchers, and other experts agree on a wide array of issues in investigating TRD. The variability in definitions of TRD, the different definitions of successful outcomes (e.g., response vs. remission), and the large number of potential risk factors substantially hampered our ability to summarize and synthesize this evidence base.

In the remainder of this chapter, we first present our key findings from both parts of the report. We then discuss core findings in terms of what is already known in the clinical and research realms and literature and explore the clinical and policymaking implications of our work. Additionally, we examine the applicability (i.e., generalizability) of our findings for patient populations, TRD interventions, and ways to measure important outcomes in trials or other studies.

Later sections of this chapter examine the limitations of both the literature itself and our ability to synthesize it adequately to address matters of interest for the Centers for Medicare & Medicaid Services (CMS). Finally, we offer a set of recommendations about needed research to address both gaps in the evidence base and common problems or drawbacks of studies to date.

## Key Findings

### Narrative Review: Definition of Treatment-Resistant Depression

#### Applying Definitions or Diagnostic Tools

No consensus definitions exist for TRD. Available definitions are anchored primarily by consideration of three key variables: number of prior treatment failures (the primary consideration), adequacy of prior treatment doses, and adequacy of prior treatment duration. These definitions address TRD mainly as a part of major depressive disorder (MDD); in contrast, within bipolar disorder, TRD definitions have centered on one prior treatment failure.

For these three variables, the most commonly used definition is a continuing depressive episode following at least two prior antidepressants treatments of at least 4 or 6 weeks of an adequate dose; as to defining adequacy, descriptions range from a minimum effective dose to a maximum tolerated dose.

Five staging models for TRD are in use, but they have only a limited evidence base supporting their validity. These models appear equally valid for documenting treatment failure in depressed patients in intervention studies, but their applicability and feasibility in clinical practice are unclear.

Consensus is also lacking about the “best” tool for diagnosing TRD in clinical research; neither is there a “most commonly used” tool. Diagnostic tools used to identify TRD emphasize careful clinical assessment for MDD, but they differ in how structured the assessment is, ranging from standard clinical assessment to a highly structured research tool. Moreover, the evidence base for validity and feasibility of such tools or instruments is limited, and the accuracy of a careful history (more feasible) and a structured tool has never been directly compared. As noted above, the limited evidence base suggests that staging models are equally valid for diagnosing TRD. Outside of feasibility (which affects use of diagnostic tools in all locations to some degree), setting does not appear to substantially influence the choice of which tool to use.

#### Measuring Outcomes or Endpoints of Studies and Observational Studies

Similarly, we could find no consensus about the best measure(s) to determine success or failure in TRD studies. Outcomes have consisted primarily of depression-specific measures; we did find agreement that remission is the preferred outcome regardless of which tool is used. Investigators have also assessed general psychiatric status, functional impairment, and various domains of quality of life, but patient-oriented outcomes are rarely assessed as primary outcomes.

Both patient-reported and clinician-administered measures are available for each category; we found no stated preference for one type over the other, although patient-reported tools are more feasible to use. The available measures appear to have adequate psychometric properties. However, the degree of validity of the general psychiatric measure Clinical Global Impression (which has two variants) is unclear. The minimally clinically important difference (MCID) has been defined for many of these measures; nevertheless, no clear consensus about a preferred definition for MCIDs has emerged.

#### Minimizing Bias and Determining Appropriate Research Study Duration

We uncovered some agreement about how best to minimize bias in research studies. Most investigators and expert groups over the past decade preferred randomized designs over nonexperimental ones. Most of the available literature did not address, or apparently achieve consensus about, designs that might minimize placebo effects. Although 6 weeks was a frequently recommended minimum study length, we found no agreement on a preferred duration of trials or observational studies, although experts frequently recommend studies longer than 4 to 6 weeks.

#### Addressing Risk Factors

Evidence addressing risk factors for TRD was quite limited. Several components of the TRD definition (disease severity, duration of current episode, number of previous hospitalizations, and number of failed antidepressant trials) appeared to be associated with greater risk of TRD. Coexisting anxious symptoms, anxiety disorders, and personality disorders were related to higher risk of TRD as well, as were specific clinical characteristics such as having melancholic features and suicidality (suicide ideation or attempts).

### Systematic Review: Current Clinical Trials and Observational Studies of Treatment-Resistant Depression

#### Classifying the Main Focus of Trials or Observational Studies

The large majority of trials or observational studies investigating TRD focused on either brain stimulation therapies (BST) or pharmacotherapy interventions. BST approaches included electroconvulsive therapy and repetitive transcranial magnetic stimulation (rTMS). Many fewer studies dealt with either psychotherapy interventions or complementary and alternative medicine (CAM) or exercise (which we generally combined). They were conducted primarily in adult, nongeriatric patient populations (i.e., 18 years of age or older, but relatively few of age 65 or older); study patients tended to have moderate depressive severity as measured by a variety of standardized instruments (e.g., Hamilton Depression Rating Scale [HAM-D]).

#### Specifying Inclusion or Exclusion Criteria for Study Entry

Aspects of specifying inclusion or exclusion criteria for study entry were rather variable. Confirmation of prior MDD diagnosis and current TRD for study entry were often poorly described. The HAM-D and the Montgomery—Åsberg Depression Rating Scale were the most commonly used instruments to set thresholds for study entry or to measure study outcomes.

Moreover, we found little consistency among studies for the necessary number (or types) of prior treatment attempts for study entry; most studies required at least one, and sometimes two, prior failed treatment attempts of adequate therapy (as described above). Several different patient characteristics were only rarely considered for study entry; these typically “historical” characteristics included duration of depressive symptoms, prior depressive relapses, prior treatment intolerance, prior augmentation or combination therapy, prior psychotherapy, or suicidality.

This variability in study inclusion criteria reflects the variability in TRD definitions reported above for the narrative review. Indeed, inclusion criteria as specified by the eligible TRD trials or observational studies generally did not closely align with TRD definitions identified in the narrative review. For example, although the most common definition of TRD we found in the narrative review involved a minimum of two failed prior treatment attempts with adequate use of an antidepressant, only 38 percent of studies we identified met that definition. Moreover, only 49 percent of studies we identified required at least a single such failed attempt. BST studies were more nikely to require a minimum of two or more failed treatment attempts, whereas pharmacologic studies were more likely to require a minimum of at least one failed attempt.

Investigators also did not systematically confirm that other key parts of a TRD diagnosis were part of their inclusion criteria. For example, 77 percent of studies considered adequate dose in their selection criteria, and only 58 percent systematically confirmed that the dose was adequate. Similarly, 82 percent of all studies considered in their selection criteria whether prior treatments were of an adequate duration; of those, only 72% systematically confirmed that the length of such earlier treatment attempts was adequate (≥4 weeks of therapy).

We note that these criteria were not strict. While our narrative review led to considering a minimum adequate treatment duration to be 4 weeks, this duration may be too short, because it barely gives antidepressants (which take approximately 4 weeks to demonstrate a clinical response at a given dose) enough time for a clear response to be observed. Similarly, our criterion for adequate dose, reflecting what was reported in the literature, set the bar relatively low at what would be considered a minimum therapeutic dose. Such a dose does not reflect what would occur in clinical situations, where dosage would be increased to a moderate level after an initial failure to achieve a robust response.

Even with this relatively lenient working definition, only 17% of studies (27/163) specified and confirmed through eligibility criteria that their population had these three most common components of the current TRD definition: a minimum of two prior treatment failures, a confirmed adequate dose, and a confirmed adequate duration of treatment (≥4 weeks). Relaxing our definition of adequacy only slightly improved this rate. When we relaxed our definition of adequacy to be that a study’s inclusion criteria merely considered adequacy of dose and duration (but did not systematically define and confirm), only 25% of studies (40/163) had inclusion criteria that met this mark.

#### Designing Studies

The majority of all the studies from our systematic review evidence base (88%) had a randomized controlled design. A very few were nonrandomized trials; the remainder were an array of observational studies.

Few of the clinical trials had run-in periods (21%) for screening out medication nonadherence, mitigating the effects of a placebo response, and/or ensuring that enrolled participants were stable enough to participate in the study. Similarly, few had wash-out periods (23%) to ensure that participants did not have certain TRD-related medications in their systems before the study began. Study duration differed markedly across these various types of studies. It ranged from less than 2 weeks to more than 4 years; more than one-half lasted 2 months or less.

#### Controlling for Potential Confounders

The great majority of all these studies (88%) used randomization to control for potential confounders. All studies applied some exclusion criteria that limited potential confounders. Severity of disease, number of prior failed treatments, psychiatric and medical comorbidities, and bipolar disease were the most commonly applied restriction factors to achieve homogeneous study populations.

Several studies stratified analyses by potential confounders, most commonly age, sex or gender, number of prior failed treatments, and duration of current depressive episode. However, as noted above, some of these factors (e.g., severity of disease, number of prior failed treatments, and duration of current episode) were neither consistently nor systematically described. Of 19 nonrandomized studies, only eight sets of investigators reported using any statistical techniques to control for potential confounding.

#### Addressing Risk Factors and Their Relationships to Outcomes

There was limited information on whether patient-level risk factors or specific study-level characteristics had an impact on results of studies in patients with TRD. In studies comparing rTMS with sham rTMS, bivariable analyses indicated that sample size, female sex, and bipolar disorder showed a statistically significant impact on measures of treatment effects. However, in multivariable analyses, however, none of these variables remained statistically significant.

In studies comparing pharmacotherapy with pharmacotherapy plus augmentation, bivariable analyses indicated that depression severity, female sex, and study duration rendered a statistically significant impact on measures of treatment effects. In multivariable analyses, however, only the effect of female sex on discontinuation because of adverse events remained statistically significant. Studies with 60 percent or more female participants had statistically significantly higher discontinuation rates because of adverse events (ROR 2.81; 95% CI 1.04 to 7.59) than studies with fewer than 60 percent females.

A smaller placebo response was associated with a statistically significantly larger treatment effect regarding response (p=0.027), remission (p=0.001), and discontinuation because of adverse events (p=0.010). Study duration did not have an impact on placebo response.

#### Identifying Key Outcomes of Studies

Depressive symptoms were the most commonly reported endpoint across all types of studies; sometimes these are denoted as the severity of depression because of the nature of the measures used to assess them. Most often, the HAM-D was used in these studies, but often the Montgomery—Åsberg Depression Rating Scale was encountered in this body of evidence. The Clinical Global Impression was the most common general psychiatric outcome reported, most often in pharmacology studies. Functional impairment and quality-of-life outcomes were infrequently reported; usually one of four well-known instruments was used, but we saw no consistent patterns for these endpoint measures.

Adverse events were commonly reported for BST and pharmacology studies, but they were not often reported in psychotherapy and CAM/exercise studies. Overall rate of attrition was a commonly reported phenomenon, but specific attributions of attrition (e.g., because of adverse events or lack or efficacy) were less commonly made.

Adherence to treatment was not commonly reported. Disability status, time to relapse, and use of health care services were mentioned or documented only very rarely.

#### Findings in Relationship to What Is Already Known

The variability in the definitions and conceptualization of TRD (from our narrative review) is quite consistent with other reports from the past decade identifying the lack of any standard, systematic definition of TRD.^18,31,44,47^ Taken all together, the available literature highlights the resulting difficulty in synthesizing information across studies (or other types of studies or documents). This characteristic of the evidence base also underscores the problems of translating research findings into guidelines for selecting better treatment options for patients with TRD. Key challenges include the lack of agreement on what constitutes adequacy of dose and duration of prior treatments, what the preferred definition of treatment success or failure is, and how best to confirm TRD both in clinical research and in clinical care.

What the narrative review newly highlights is how the great variability in information from systematic reviews and influential nonsystematic reviews is reflected in the great variability of guidelines and consensus statements about managing patients with TRD. Although a minimum of two prior treatment failures appears most commonly in both systematic reviews and guidelines or consensus statements, defining the adequacy of dose and duration, clarifying failure (as remission or response, and after what length of time), and determining whether TRD requires the prior use of different classes of antidepressants are all variably defined and implemented. This lack of agreement complicates both developing and administering patient management guidelines.

Our systematic review highlighted some key findings not previously described. The mismatch between the most common number of treatment failures (at least two) and what most of the recent literature has assessed (at least one) was stark. Also, the failure of inclusion criteria in recent TRD studies to confirm systematically both adequate dose (58%) and duration (72%) has not been described previously, nor has the finding that only 17 percent of recent intervention studies are consistent with the most common definition of TRD. These results highlight another concern about how to compare and synthesize data across treatment studies.

Finally, despite the substantial morbidity associated with TRD, the relative infrequency of use of patient-oriented outcomes such as functional impairment and quality-of-life measures in considering the benefits of TRD treatment was newly demonstrated. So, too, was the infrequent measurement of both adherence to treatment and health care services use.

### Implications for Clinical and Policy Decisionmaking

This current state of evidence underscores the challenges facing clinicians. A substantial body of literature addresses TRD, but the absence of standard, systematized identification and management approaches in the TRD database makes it difficult to translate this evidence efficiently to establish clinical practice guidelines for care. The greatest concern is the heterogeneity in identifying TRD per se and in how (and when) to determine treatment failure. Effective treatments exist, but because of this variability, determining to which TRD patients the results apply is difficult.

Similarly, the state of the evidence poses challenges for policymakers. Officials at CMS, other public agencies, and private-sector organizations must be confident that two main assumptions are being met: first, that the population of patients with TRD is being consistently and systematically defined, and second, that meaningful and comparable outcomes of importance to both patients and clinicians are being monitored. Neither is consistently reported in the literature, limiting translation of this treatment information into actual care. Given the high levels of significant health effects within the TRD population, the administration of effective interventions is vital.

Despite this variability, we see several important implications from the available evidence base. The high level of morbidity associated with TRD is clear, and the literature suggests that, at a minimum, TRD can be understood as two or more prior treatment failures of an adequate treatment dose (at least minimally effective) and an adequate treatment duration (approximately 4 or more weeks of treatment). For adequate clinical and policy decisionmaking about TRD patients, however, a widely agreed-upon definition of the condition that addresses how to determine the number of prior treatment failures and the adequacy of dose and duration is critical. Some means of consistently and systematically monitoring TRD on a large scale (e.g., a treatment registry using common data elements in an electronic medical record) could substantially help clarify which criteria best define TRD, what the course of illness is, and how interventions might affect that course.

### Limitations of this Technology Assessment

#### Comparative Effectiveness Review Process

The primary challenge of this process was the broad, comprehensive, and inclusive nature of the topic, which combined a narrative review (for five KQs) and a systematic one (for six KQs). Given how variable the definitions of TRD are in the literature, we needed to cast a wide net for both published and gray literature to assemble the proper universe of sources that could be managed within a reasonable amount of time and resources. This requirement produced important information but also a considerable amount of materials that proved to be of little or no utility.

Once we identified each article or item from either the peer-reviewed or gray literature, we abstracted large amounts of information. Then, we tried to harmonize information across articles and other sources. However, these data items were not always directly comparable. Critical examples include the following: some articles might say one failure of a prior treatment attempt, others might say one or more, and yet others might say one to three, which sometimes precluded organizing studies into easily recognizable, meaningful, and comparable categories; moreover, some articles systematically define a treatment duration, but others do not.

We addressed this challenge by focusing the 11 KQs and the time periods for the literature searches to reflect the current conceptualization of TRD. For example, we limited our systematic review search to the past 10 years to focus on the contemporary understanding of this serious condition.

Also, some questions proved particularly challenging. For example, KQ 3 has, as part of the question, a consideration of psychometric properties and what amount to MCIDs. These are extremely important concepts, but the scope of this particular technology assessment did not accommodate a comprehensive (systematic) literature search for information about these topics. Accordingly, the information reported was what has been reported in a general (but not systematic) search for relevant reviews or summaries.

#### The Evidence Base

The primary limitation of this evidence base is the heterogeneity of TRD definitions encountered in both the narrative review of TRD definitions and the systematic review of the studies. In the narrative review, although most study authors used a definition of one or more prior treatment failures, they did not, overall, yield any agreement about a correct measure. More importantly, the definitions of an adequate dose and duration varied considerably. This unevenness was reflected in the inconsistency of inclusion criteria of even the systematically identified clinical trials selected for the systematic review, where even the most frequent count of prior adequate trial failures—two—was not the most common minimum used in studies. Agreed-upon definitions of adequacy of dose and duration of prior studies were also absent; this gap perhaps led to the infrequency of systematically and consistently confirming these parts of the definition in clinical trials. Findings also do not account for the high level of heterogeneity of patients who have TRD; we encountered considerable variability in such basic parameters as how many interventions were tried in the past, the types of symptoms and their duration and severity, and presence of numerous coexisting physical or mental health conditions.

As a result, at the core of the limitations in this evidence base is that with no agreed-upon definition of TRD and no consensus on very important outcomes, determining to what population clinical trials results apply is difficult. This heterogeneity will prevent others from synthesizing or combining data, even for the more common TRD interventions such as brain stimulation technologies or medications, to translate findings into clinical practice recommendations.

### Research Recommendations

We propose several steps to address existing evidence gaps and substantially improve the study and treatment of TRD. Many of these steps speak to the clinicians and researchers who work with TRD patients; others are aimed more at organizations that support this type of research. In either case, the points are pertinent to all audiences.

Reducing the heterogeneity of how TRD patient populations are defined is a necessary first step to improving the evidence base. Perhaps the most critical step is to reach agreement on a standardized, systematic, and feasible definition of TRD. Such a definition should clearly specify the number of prior treatment attempts, what an adequate dose is, and what an adequate duration is. At the very least, the minimum number of past failed therapy attempts should be two. Systematic confirmation of adequacy is a necessary part of this “definitional” step.

Systematic, standardized accounting for potential confounders is also crucial. The factors that must be considered include, at a minimum, the following: depressive severity, duration of current episode, prior treatment intolerance, prior augmentation or combination therapy, prior psychotherapy, and psychiatric comorbidities. Other socio-cultural factors that may influence the course of TRD (e.g., gender and age) may also be relevant and deserve further study, as may genetic factors.^42^ Randomization can account for some measured and unmeasured confounders in larger trials, but the smaller RCTs that we identified, which had imbalances in baseline characteristics, rarely adjusted for such differences. Moreover, nonrandomized TRD studies adjusted for potential confounders less than one-half the time, for example. Acting on how best to deal with confounders is essential to improving this evidence base.

Agreement on a core package of outcome measures to be administered in a standard manner should be strongly encouraged. The field would benefit from an evidence-informed, multistakeholder consensus process to develop a core outcome set for TRD, potentially something similar to the Outcome Measures in Rheumatology process in rheumatology (https://www.omeract.org/). Of particular importance is including one measure of depressive severity, one measure of general psychiatric status, one measure of functional impairment or quality of life, and one measure of adherence to medications or other interventions. Another key outcome to consider includes a measure of suicidality (to assess for reduction in suicidality). Common use of measures will allow for better comparisons among trials; doing so should improve our ability to combine studies for meta-analyses. Patient-reported instruments may be preferred because they are more feasible, generally speaking, and more patient centered than clinician-reported instruments; examples of such self-report scales addressing functional impairment include the Sheehan Disability Scale.^128^

Researchers and clinicians should come to consensus on a standard length of treatment. The key is to provide enough time for patients to receive an adequate dose and duration of the intervention. Given the chronicity of TRD and the time to reach an adequate dose and length of treatment, at least 2 months is the bare minimum for studies to be conducted. Also, the increasing risk of relapse with greater levels of resistance^7^ argues for the need to demonstrate longer-term efficacy for the more-resistant patients, suggesting a need for even longer trials for the more severely resistant. For this latter group, who may have a more chronic and persistent course, different treatments might be required than for those whose depressive episodes are more episodic.

Whether either run-in stages or wash-out periods affect the efficacy or effectiveness of TRD treatments remains unclear. Comparative trials should examine this issue to clarify whether investigators should use one or the other in designing their trials.

We found (and were able to include) only a very few studies of interventions other than pharmacological or BST interventions (that is, psychotherapies and CAM or exercise as remedies for TRD). This gap reduced the evidence base relevant for patients who prefer to avoid, or for whom it would be inappropriate to try, pharmacological agents or more invasive procedures. Consideration of less-studied interventions could help inform patient decisions about options and improve the level of shared or informed decisionmaking.

Trials or other robust types of observational studies to test the effectiveness of all such interventions in real-world settings are necessary. Targeting only efficacy (via RCTs) may produce information for clinicians, patients, or policymakers that cannot easily be applied in “ordinary,” every-day circumstances. At the same time, intervention trials should not be limited to such comparative effectiveness methods. Indeed, some experts suggest taking a broader perspective—one that would have the field also pursue basic efficacy research (e.g., “does this new intervention work compared to placebo?”) and translational strategies (e.g., “how do we disseminate this intervention that we know works into real-world settings?”) to improve clinicians’ and policymakers’ understanding of TRD. Among the ideas along these lines are that intervention studies should indeed include more modalities (e.g., psychotherapies), but also examine “experimental therapeutics”^141^ and a translational approach that may incorporate designs that go beyond traditional trials and feature more patient engagement.

To allow for better assessment of quality, publications of RCTs need to adhere to Consolidated Standards of Reporting Trials (CONSORT) specifications for reporting.^48^ Similarly, publications of nonrandomized controlled trials or observational studies should adhere to Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) guidelines.^49^ Documenting all steps in such investigations, reporting on all planned outcomes, and otherwise ensuring complete transparency for this work are critical actions in adding to the professional literature. These steps would help ensure a consistent definition of TRD and its reported outcomes.

Finally, TRD needs to be monitored consistently, systematically, and on a large scale. For instance, a treatment registry making use of common data elements in an electronic medical record could substantially help clarify which criteria best define TRD, what the course of illness is, and how interventions might affect that course. Coordination between different specific treatment registries that already exist (e.g., the vagal nerve stimulation registry required by the FDA,^50,51^ and the transcranial magnetic stimulation registry recently launched by Neurostar^52^) and have been suggested (e.g., a ketamine registry^53^) would be a necessary step. Data quality would be a key challenge for such an enterprise.

### Conclusions

Our basic assignment from the Agency for Healthcare Research and Quality and CMS was to consider a wide array of “study design” issues relating to trials (or observational studies) of TRD therapies. Across all 11 of the complex topics addressed in this Technology Assessment, we encountered substantial diversity at every stage of research on TRD interventions. Of particular concern was the lack of consensus about various elements of even a TRD diagnosis and appropriate inclusion or exclusion criteria. Additionally, little or no agreement about important outcomes and how to assess them hampered analysis. An extensive set of recommendations about more and more-robust approaches to the design and conduct of this research will foster better evidence to translate into clearer guidelines for treating patients with this serious condition.